# Appendix J Network Meta-Analysis Results for Glycemic Control and Age Subgroup Analyses

Table J1 Network meta-analysis results for HbA_1c_ for suboptimal glycemic control subgroup (HbA_1c_ ≥7%)

Arm Description | Rank Order of Effect & Studies (only those removed from original analysis) | Intensity | Method of Communication | Delivery Method | Delivery Personnel | MD, 95% Credibility Interval | Probability of Being Best
Usual care | NA1-6 | NA | NA | NA | NA | 0 [NA, NA] | 0.0%
Active comparator (non-DSME) | 28^7^ | NA | NA | NA | NA | -0.10 [-0.34, 0.15] | 0.0%
Active comparator (other) | 24^8, 9^ | NA | NA | NA | NA | -0.14 [-0.55, 0.26] | 0.0%
DSME | 22 | ≤10h | In person | Individual & mixed | HCP | -0.17 [-0.40, 0.07] | 0.0%
DSME | 20 | ≤10h | In person | Group only | HCP | -0.20 [-0.47, 0.07] | 0.0%
DSME | 29 | ≤10h | In person | Group only | Non-HCP | -0.03 [-0.96, 0.90] | 0.4%
DSME | 26 | ≤10h | Some technology | Individual & mixed | HCP | -0.11 [-0.41, 0.18] | 0.0%
DSME | 21^1^ | ≤10h | Some technology | Individual & mixed | Non-HCP | -0.18 [-0.48, 0.11] | 0.0%
DSME | 17 | 11-26h | In person | Individual & mixed | HCP | -0.26 [-0.72, 0.20] | 0.0%
DSME | 18^3, 6^ | 11-26h | In person | Group only | HCP | -0.26 [-0.48, -0.04] | 0.0%
DSME | 15^2, 4^ | 11-26h | In person | Group only | Non-HCP | -0.34 [-0.78, 0.10] | 0.0%
DSME | 25 | 11-26h | Some technology | Individual & mixed | HCP | -0.12 [-0.47, 0.22] | 0.0%
DSME | 4 | 11-26h | Some technology | Individual & mixed | Non-HCP | -0.78 [-1.37, -0.18] | 5.3%
DSME | 27 | 11-26h | Some technology | Group only | HCP | -0.11 [-1.16, 0.93] | 1.3%
DSME | 7 | ≥27h | In person | Individual & mixed | HCP | -0.73 [-1.61, 0.14] | 10.1%
DSME | 31^7^ | ≥27h | In person | Group only | HCP | 0.09 [-0.49, 0.68] | 0.0%
DSME | 9 | ≥27h | Some technology | Individual & mixed | HCP | -0.70 [-1.60, 0.21] | 9.3%
DSME + Support | 8 | ≤10h | In person | Individual & mixed | NA | -0.70 [-1.52, 0.12] | 7.7%
DSME + Support | 34 | ≤10h | In person | Group only | NA | 2.83 [1.48, 4.20] | 0.0%
DSME + Support | 16 | ≤10h | Some technology | Individual & mixed | NA | -0.30 [-0.74, 0.13] | 0.0%
DSME + Support | 10 | 11-26h | In person | Individual & mixed | NA | -0.64 [-1.70, 0.43] | 10.5%
DSME + Support | 6 | 11-26h | In person | Group only | NA | -0.73 [-1.38, -0.10] | 4.0%
DSME + Support | 13 | 11-26h | Some technology | Individual & mixed | NA | -0.36 [-0.86, 0.12] | 0.0%
DSME + Support | 11 | ≥27h | In person | Individual & mixed | NA | -0.55 [-1.08, -0.02] | 0.6%
DSME + Support | 3 | ≥27h | In person | Group only | NA | -0.88 [-1.66, -0.10] | 14.4%
Lifestyle | 33^5^ | ≤10h | In person | Individual & mixed | NA | 0.50 [-0.35, 1.34] | 0.0%
Lifestyle | 23^9^ | ≤10h | In person | Group only | NA | -0.15 [-1.16, 0.88] | 1.4%
Lifestyle | 35 | ≤10h | Some technology | Individual & mixed | NA | 0.40 [-0.83, 1.62] | 0.4%
Lifestyle | 12 | 11-26h | In person | Individual & mixed | NA | -0.41 [-0.82, 0.01] | 0.0%
Lifestyle | 5 | 11-26h | In person | Group only | NA | -0.76 [-1.19, -0.33] | 1.8%
Lifestyle | 1 | 11-26h | Some technology | Individual & mixed | NA | -1.01 [-1.61, -0.40] | 19.4%
Lifestyle | 19 | 11-26h | Some technology | Group only | NA | -0.20 [-0.99, 0.59] | 0.4%
Lifestyle | 2^8^ | ≥27h | In person | Individual & mixed | NA | -0.98 [-1.47, -0.50] | 12.9%
Lifestyle | 30 | ≥27h | In person | Group only | NA | 0.02 [-0.51, 0.57] | 0.0%
Lifestyle | 25 | ≥27h | Some technology | Individual & mixed | NA | -0.34 [-0.80, 0.11] | 1.3%

DSME = diabetes self-management education; h = hour(s); HCP = health care professional; MD = mean difference; NA = not applicable

Table J2 Network meta-analysis results for HbA_1c_ for participants under 65 years of age

Arm Description | Rank Order of Effect & Studies(only those removed from original analysis) | Intensity | Method of Communication | Delivery Method | Delivery Personnel | MD, 95% Credibility IntervaI | Probability of Being Best
Usual care | NA2, 3, 10-14 | NA | NA | NA | NA | 0 [NA, NA] | 0.0%
Active comparator (non-DSME) | 31 | NA | NA | NA | NA | 0.12 [-0.23, 0.46] | 0.0%
Active comparator (other) | 12^15, 16^ | NA | NA | NA | NA | -0.54 [-1.19, 0.10] | 0.0%
DSME | 18^16^ | ≤10h | In person | Individual & mixed | HCP | -0.33 [-0.68, 0.02] | 0.0%
DSME | 21 | ≤10h | In person | Group only | HCP | -0.22 [-0.63, 0.19] | 0.0%
DSME | 29 | ≤10h | In person | Group only | Non-HCP | -0.05 [-1.31, 1.21] | 0.8%
DSME | 27^12^ | ≤10h | Some technology | Individual & mixed | HCP | -0.09 [-0.51, 0.32] | 0.0%
DSME | 25^13^ | ≤10h | Some technology | Individual & mixed | Non-HCP | -0.15 [-0.55, 0.24] | 0.0%
DSME | 23 | 11-26h | In person | Individual & mixed | HCP | -0.17 [-0.83, 0.50] | 0.0%
DSME | 20^3, 11^ | 11-26h | In person | Group only | HCP | -0.26 [-0.58, 0.06] | 0.0%
DSME | 17^2^ | 11-26h | In person | Group only | Non-HCP | -0.38 [-0.97, 0.20] | 0.0%
DSME | 28^10^ | 11-26h | Some technology | Individual & mixed | HCP | -0.06 [-0.63, 0.50] | 0.0%
DSME | 5 | 11-26h | Some technology | Individual & mixed | Non-HCP | -0.78 [-1.60, 0.04] | 3.4%
DSME | 26 | 11-26h | Some technology | Group only | HCP | -0.11 [-1.46, 1.22] | 1.6%
DSME | 7 | ≥27h | In person | Individual & mixed | HCP | -0.73 [-1.92, 0.45] | 7.7%
DSME | 1 | ≥27h | In person | Group only | HCP | -1.42 [-2.12, -0.72] | 37.3%
DSME | 13 | ≥27h | Some technology | Individual & mixed | HCP | -0.49 [-1.72, 0.75] | 3.8%
DSME + Support | 8 | ≤10h | In person | Individual & mixed | NA | -0.71 [-1.85, 0.44] | 6.5%
DSME + Support | 34 | ≤10h | In person | Group only | NA | 2.82 [1.14, 4.48] | 0.0%
DSME + Support | 19^16^ | ≤10h | Some technology | Individual & mixed | NA | -0.27 [-1.05, 0.51] | 0.1%
DSME + Support | 15 | 11-26h | In person | Individual & mixed | NA | -0.43 [-1.77, 0.93] | 4.2%
DSME + Support | 6 | 11-26h | In person | Group only | NA | -0.74 [-1.58, 0.10] | 2.4%
DSME + Support | 16 | 11-26h | Some technology | Individual & mixed | NA | -0.39 [-1.09, 0.31] | 0.1%
DSME + Support | 11 | ≥27h | In person | Individual & mixed | NA | -0.54 [-1.32, 0.23] | 0.8%
DSME + Support | 4 | ≥27h | In person | Group only | NA | -0.88 [-1.89, 0.12] | 8.5%
Lifestyle | 32 | ≤10h | In person | Individual & mixed | NA | 0.21 [-0.51, 0.95] | 0.0%
Lifestyle | 10 | ≤10h | In person | Group only | NA | -0.60 [-1.62, 0.41] | 2.3%
Lifestyle | 33 | ≤10h | Some technology | Individual & mixed | NA | 0.26 [-1.13, 1.65] | 0.5%
Lifestyle | 14^14^ | 11-26h | In person | Individual & mixed | NA | -0.45 [-1.06, 0.16] | 0.0%
Lifestyle | 9 | 11-26h | In person | Group only | NA | -0.68 [-1.27, -0.09] | 0.4%
Lifestyle | 3 | 11-26h | Some technology | Individual & mixed | NA | -0.91 [-1.75, -0.06] | 6.6%
Lifestyle | 22 | 11-26h | Some technology | Group only | NA | -0.20 [-1.32, 0.92] | 0.9%
Lifestyle | 2 | ≥27h | In person | Individual & mixed | NA | -1.17 [-1.81, -0.55] | 11.7%
Lifestyle | 30 | ≥27h | In person | Group only | NA | 0.08 [-0.70, 0.86] | 0.0%
Lifestyle | 24^15^ | ≥27h | Some technology | Individual & mixed | NA | -0.16 [-0.94, 0.62] | 0.1%

DSME = diabetes self-management education; h = hour(s); HCP = health care professional; MD = mean difference; NA = not applicable

## References for Appendix J

1 Lorig K, Ritter PL, Laurent DD, et al. (2010). Online diabetes self-management program: a randomized study. Diabetes Care.
2 Lorig K, Ritter PL, Villa FJ, et al. (2009). Community-based peer-led diabetes self-management: a randomized trial. Diabetes Educ.
3 Sarkadi A, Rosenqvist U. (2004). Experience-based group education in type 2 diabetes: a randomised controlled trial. Patient Educ Couns.
4 Vincent D, Pasvogel A, Barrera L. (2007). A feasibility study of a culturally tailored diabetes intervention for Mexican Americans. Biol Res Nurs.
5 Welschen LMC, Van Oppen P, Bot SDM, et al. (2013). Effects of a cognitive behavioural treatment in patients with type 2 diabetes when added to managed care: a randomised controlled trial. J Behav Med.
6 Yuan C, Lai CW, Chan LW, et al. (2014). The effect of diabetes self-management education on body weight, glycemic control, and other metabolic markers in patients with type 2 diabetes mellitus. J Diabetes Res.
7 McGwan P. (2011). The efficacy of diabetes patient education and self-management education in type 2 diabetes. Can.
8 Giannopoulou I, Fernhall B, Carhart R, et al. (2005). Effects of diet and/or exercise on the adipocytokine and inflammatory cytokine levels of postmenopausal women with type 2 diabetes. Metabolism.
9 Johnson ST, Bell GJ, Mccargar LJ, et al. (2009). Improved cardiovascular health following a progressive walking and dietary intervention for type 2 diabetes. Diabetes Obes Metab.
10 Bond GE, Burr R, Wolf FM, et al. (2007). The effects of a web-based intervention on the physical outcomes associated with diabetes among adults age 60 and older: a randomized trial. Diabetes Technol Ther.
11 Chan LS. (2012). Chronic disease self-management in Hong Kong Chinese older adults living in the community. Dissertation Abstracts International: Section B: The Sciences and Engineering.
12 Moriyama M, Nakano M, Kuroe Y, et al. (2009). Efficacy of a self-management education program for people with type 2 diabetes: results of a 12 month trial. Jpn J Nurs Sci.
13 Ruggiero L, Moadsiri A, Butler P, et al. (2010). Supporting diabetes self-care in underserved populations: a randomized pilot study using medical assistant coaches. Diabetes Educ.
14 Sung K, Bae S. (2012). Effects of a regular walking exercise program on behavioral and biochemical aspects in elderly people with type II diabetes. Nurs Health Sci.
15 Dunstan DW, Daly RM, Owen N, et al. (2005). Home-based resistance training is not sufficient to maintain improved glycemic control following supervised training in older individuals with type 2 diabetes. Diabetes Care.
16 Skelly AH, Carlson J, Leeman J, et al. (2009). Controlled trial of nursing interventions to improve health outcomes of older African American women with type 2 diabetes. Nurs Res.