# Appendix I Effectiveness Across Outcomes for Type 2 Diabetes Mellitus

Table I1 Effectiveness of behavioral programs compared with usual care for type 2 diabetes

Category | Outcomes | Timepoint
Category | Outcomes | EOI | | 6m | | 12m
Category | Outcomes | # Comparisons (# Subjects) | Study Effect | # Comparisons (# Subjects) | Study Effect | # Comparisons (# Subjects) | Study Effect
Clinical Outcomes | Glycemic Control (HbA_1c_) | 66 (8,715)1-63 | MD, -0.35; 95% CI -0.56 to -0.14; I^2^ =74% | 23 (4,138)14, 33, 45, 51, 53, 62, 64-78 | MD, -0.16; 95% CI -0.36 to 0.04; I^2^=61% | 9 (1,494)14, 40, 67-69, 71, 78, 79 | MD, -0.14; 95% CI -0.4 to 0.12; I^2^=59%
Clinical Outcomes | Change in Body Composition (BMI) | 36 (4,280)1-3, 6, 8-10, 12, 13, 15, 18, 19, 21, 22, 27, 29, 30, 32, 33, 41, 43, 47, 49-51, 53, 56, 57, 60, 62, 63, 77, 80, 81 | MD, -0.51; 95% CI -0.66 to -0.36; I^2^ =54% | 14 (1,840)33, 51, 53, 62, 64, 66-68, 70, 71, 75, 77, 81 | MD, -0.21; 95% CI -0.32 to -0.1; I^2^ =0% | 5 (867)67, 68, 71, 82, 83 | MD, -0.92; 95% CI -1.44 to -0.4; I^2^ =0%
Clinical Outcomes | Weight (kg) | 37 (4,070)2, 4, 6, 7, 9, 11, 17, 19, 20, 22, 23, 25, 26, 31, 32, 35, 39, 41-43, 49, 53, 55, 58-63, 69, 77, 84-86 | MD, -1.68; 95% CI -2.06 to -1.30; I^2^ =53% | 8 (1,714)53, 62, 68, 74, 77, 78, 84 | MD, -0.22; 95% CI -0.56 to 0.12; I^2^=0% | 1 (291)68 | MD, -1.60; 95% CI -5.41 to 2.21; I^2^=NA
Clinical Outcomes | Change in Body Composition (% body fat) | 2 (73)26, 60 | MD, -3.34; 95% CI -4.57 to -2.11; I^2^=0% | NA | NA | NA | NA
Clinical Outcomes | Change in Body Composition (waist circumference [cm]) | 17 (1,521)6, 9, 12, 22, 25, 32, 33, 41, 43, 51, 55, 56, 60, 62, 84 | MD, -3.17; 95% CI -4.36 to -1.98; I^2^ =64% | 6 (690)33, 51, 62, 68, 84 | MD, -1.09; 95% CI -2.7 to 0.52; I^2^=10% | 2 (385)68, 82 | MD, -2.92; 95% CI -11.3 to 5.46; I^2^=0%
Clinical Outcomes | Total Cholesterol (mmol/l) | 27 (2,633)2, 6-9, 16-18, 20-22, 25, 29, 31-33, 42, 48, 49, 51, 55, 60, 62, 63 | MD, -0.1; 95% CI -0.11 to -0.09; I^2^ =0% | 7 (686)33, 51, 53, 62, 66, 68 | MD, -0.24; 95% CI -0.39 to -0.09; I^2^ =0% | 1 (291)68 | MD, -0.10; 95% CI -0.34 to 0.14; I^2^=NA
Clinical Outcomes | HDL Cholesterol (mmol/l) | 25 (2,733)1, 2, 6, 7, 9, 16-18, 20-22, 29-33, 41, 48, 49, 55, 60, 62, 63 | MD, 0.02; 95% CI 0.02 to 0.02; I^2^ =7% | 4 (563)33, 53, 62, 68 | MD, -0.09; 95% CI -0.12 to -0.06; I^2^ =0% | 1 (291)68 | MD, 0.00; 95% CI -0.20 to 0.20; I^2^=NA
Clinical Outcomes | LDL Cholesterol (mmol/l) | 27 (3,063)1-3, 6, 9, 12, 13, 18, 21, 22, 28-33, 41, 47-49, 51, 55, 60, 62, 63 | MD, -0.03; 95% CI -0.03 to -0.03; I^2^ =59% | 5 (457)33, 51, 62, 68 | MD, -0.19; 95% CI -0.47 to 0.09; I^2^=49% | 1 (291)68 | MD, 0.00; 95% CI -0.09 to 0.09; I^2^=NA
Clinical Outcomes | Triglycerides (mmol/l) | 24 (2,561)1, 2, 6, 9, 14, 18, 21, 22, 25, 29-33, 41, 42, 48, 49, 55, 60, 62, 63 | MD, -0.17; 95% CI -0.24 to -0.1; I^2^ =36% | 5 (712)14, 33, 53, 62, 68 | MD, -0.18; 95% CI -0.37 to 0.01; I^2^=6% | 1 (291)68 | MD, -0.20; 95% CI -0.45 to 0.05; I^2^=NA
Clinical Outcomes | Systolic Blood Pressure (mmHg) | 36 (4,776)1-4, 6, 7, 9, 10, 12-14, 18, 21, 22, 25, 26, 28-30, 32, 33, 39, 41, 42, 47, 49, 51, 53, 58, 60, 62, 63, 80, 84 | MD, -0.78; 95% CI -1.3 to -0.26; I^2^ =23% | 10 (1,613)14, 33, 51, 53, 62, 68, 78, 84 | MD, -1.08; 95% CI -2.9 to 0.74; I^2^=0% | 1 (291)68 | MD, -2.80; 95% CI -7.69 to 2.09; I^2^=NA
Clinical Outcomes | Diastolic Blood Pressure (mmHg) | 33 (4,583)1-4, 6, 7, 9, 10, 12, 13, 18, 21, 22, 25, 26, 28-30, 32, 39, 41, 42, 47, 49, 53, 58, 60, 62, 63, 80, 84 | MD, -0.94; 95% CI -1.32 to -0.56; I^2^ =32% | 7 (1,424)33, 53, 62, 68, 78, 84 | MD, -1.26; 95% CI -1.97 to -0.55; I^2^ =0% | 1 (291)68 | MD, -2.20; 95% CI -4.73 to 0.33; I^2^=NA
Clinical Outcomes | Depression Symptoms | 13 (1,751)5, 7, 17, 21, 32-34, 38, 49, 53, 61, 62 | SMD, -0.16; 95% CI -0.32 to 0; I^2^ =45% | 5 (1,189)33, 53, 62, 72, 74 | SMD, -0.09; 95% CI -0.57 to 0.39; I^2^=80% | NA | NA
Clinical Outcomes | Anxiety Symptoms | NA | NA | NA | NA | NA | NA
Behavioral Outcomes | Change in Physical Activity - Duration/Intensity (Subjective [days/week]) | 7 (1,176)19, 37, 43, 49, 50, 54, 83 | MD, 0.56; 95% CI -0.1 to 1.22; I^2^=79% | 2 (270)68, 87 | MD, 1.73; 95% CI -8.82 to 12.28; I^2^=91% | 2 (382)68, 83 | MD, 0.90; 95% CI 0.9 to 0.9; I^2^ =0%
Behavioral Outcomes | Change in Physical Activity - Duration/Intensity (Objective) | 5 (373)20, 23, 39, 48 | SMD, 0.49; 95% CI -0.24 to 1.22; I^2^=74% | NA | NA | NA | NA
Behavioral Outcomes | Change in Physical Activity – Fitness | 2 (329)15, 60 | SMD, 0.67; 95% CI -7.37 to 8.71; I^2^=90% | 1 (134)67 | SMD, 0.03; 95% CI -0.30 to 0.37; I^2^=NA | 1 (134)67 | SMD, 0.11; 95% CI -0.23 to 0.44; I^2^=NA
Behavioral Outcomes | Change in Physical Activity – Strength | NA | NA | NA | NA | NA | NA
Behavioral Outcomes | Change in Dietary Intake – Energy Intake (kcal/day) | 11 (1,164)1, 2, 10, 20, 23, 33, 34, 60, 84, 88 | MD, -149.62; 95% CI -243.01 to -56.23; I^2^ =68% | 3 (469)33, 68, 84 | MD, -64.05; 95% CI -96.44 to -31.66; I^2^ =0% | 1 (191)68 | MD, 114.00; 95% CI -308.19 to 536.19; I^2^=NA
Behavioral Outcomes | Change in Dietary Intake – Saturated Fat Intake (% of daily kcal) | 10 (1,208)2, 10, 20, 33, 34, 49, 50, 60, 88 | MD, -0.24; 95% CI -0.73 to 0.25; I^2^=44% | 2 (232)33, 68 | MD, -0.40; 95% CI -8.82 to 8.02; I^2^=23% | 1 (191)68 | MD, -1.10; 95% CI -2.22 to 0.02; I^2^=NA
Behavioral Outcomes | Adherence to Medication (higher scores desirable) | 4 (742)13, 15, 54, 83 | SMD, -0.17; 95% CI -0.7 to 0.36; I^2^=75% | 1 (54)87 | SMD, 0.42; 95% CI -0.12 to 0.96; I^2^=NA | 1 (191)83 | SMD, -0.50; 95% CI -0.79 to -0.21; I^2^ =NA
Health Outcomes | Quality of Life – SF-36 Physical (higher score desirable) | 5 (787)10, 32, 39, 49 | MD, 0.45; 95% CI -0.05 to 0.95; I^2^=0% | NA | NA | NA | NA
Health Outcomes | Quality of Life – SF-36 Mental (higher score desirable) | 5 (787)10, 32, 39, 49 | MD, 1.60; 95% CI -1.96 to 5.16; I^2^=86% | NA | NA | NA | NA
Health Outcomes | Quality of Life – Other (higher score desirable) | 4 (447)27, 43, 53, 54 | SMD, 0.12; 95% CI -0.26 to 0.5; I^2^=40% | 3 (789)53, 73, 74 | SMD, 0.08; 95% CI -0.11 to 0.27; I^2^=0% | NA | NA
Health Outcomes | Diabetes-specific Quality of Life – Diabetes Distress (PAID) (lower scores desirable) | 8 (1,384)5, 7, 36, 42-44, 47, 75 | MD, -1.82; 95% CI -3.43 to -0.21; I^2^ =0% | 4 (1,382)67, 75, 78 | MD, -1.89; 95% CI -4.37 to 0.59; I^2^=0% | 3 (757)67, 78 | MD, -1.30; 95% CI -5.84 to 3.24; I^2^=0%
Health Outcomes | Diabetes-specific Quality of Life – Other (lower scores desirable) | 5 (753)15, 17, 20, 21, 33, 54 | SMD, -0.21; 95% CI -0.55 to 0.13; I^2^=51% | 3 (366)33, 67, 68 | SMD, -0.04; 95% CI -0.38 to 0.3; I^2^=0% | 2 (325)67, 68 | SMD, -0.09; 95% CI -1.15 to 0.97; I^2^=0%
Health Outcomes | Mortality – All cause (longest followup) | 25 (4,659)5, 14, 20, 28, 35, 39-43, 53, 64, 68, 69, 78, 79, 82-84 | RR, 1.28; 95% CI 0.84 to 1.94; I^2^=1% | NA | NA | NA | NA
Health Care Utilization | Emergency Department Visits (previous 6 months) | NA | NA | 2 (762)73, 74 | MD, -0.07; 95% CI -0.7 to 0.56 | NA | NA
Health Care Utilization | Days of Hospital Stay (previous 6 months) | NA | NA | 2 (646)73, 74 | MD, 0.24; 95% CI -1.52 to 2.0 | NA | NA
Program Acceptability | Participant Attrition (longest followup) | 81 (14,154)1-6, 8, 10-22, 24, 26-34, 36-44, 47, 49, 52-70, 72-87, 89 | RR, 1.11; 95% CI 0.82 to 1.49; I^2^=43% | NA | NA | NA | NA

BMI = body mass index; CI = confidence interval; EOI = end of intervention; HbA_1c_ = hemoglobin A_1c_; I^2^ = statistical heterogeneity; kg = kilograms; m = month; MD = mean difference; NA = not applicable; RR = risk ratio; SMD = standardized mean difference

Table I2 Effectiveness of behavioral programs compared with active control for type 2 diabetes

Category | Outcomes | Timepoint
Category | Outcomes | EOI | | 6m followup | | 12m followup
Category | Outcomes | # Comparisons (# Subjects) | Study Effect | # Comparisons (# Subjects) | Study Effect | # Comparisons (# Subjects) | Study Effect
Clinical Outcomes | Glycemic Control (HbA_1c_) | 25(7,518)15, 19, 23, 59, 90-104 | MD, -0.24; 95% CI -0.41 to -0.07; I^2^ =70% | 6 (595)103, 105-108 | MD, -0.19; 95% CI -0.37 to -0.01; I^2^ =0% | 6 (486)92, 99, 103, 108 | MD, -1.10; 95% CI -2.56 to 0.36; I^2^=98%
Clinical Outcomes | Change in Body Composition (BMI) | 10 (1,323)15, 19, 90, 96-99, 101 | MD, -0.52; 95% CI -1.08 to 0.04; I^2^=66% | 1 (38)105 | MD, -2.20; 95% CI -6.80 to 2.40; I^2^=NA | 2 (181)99 | MD, -0.30; 95% CI -0.3 to -0.3; I^2^ =0%
Clinical Outcomes | Weight (kg) | 15 (6,212)19, 23, 59, 90, 93, 94, 96-98, 100, 101, 104, 109 | MD, -1.30; 95% CI -2.48 to -0.12; I^2^ =78% | 3 (439)105, 106, 108 | MD, 0.14; 95% CI -3.41 to 3.69; I^2^=67% | 1 (95)108 | MD, 3.70; 95% CI 1.67 to 5.73; I^2^ =NA
Clinical Outcomes | Change in Body Composition (% body fat) | NA | NA | NA | NA | NA | NA
Clinical Outcomes | Change in Body Composition (waist circumference [cm]) | 5 (5,332)94, 96, 98, 101, 104 | MD, -2.54; 95% CI -5.78 to 0.7; I^2^=79% | 1 (38)105 | MD, -5.70; 95% CI -6.54 to -4.86; I^2^ =NA | NA | NA
Clinical Outcomes | Total Cholesterol (mmol/l) | 8 (928)90, 93, 96, 97, 99, 109 | MD, -0.26; 95% CI -0.46 to -0.06; I^2^ =50% | 1 (167)106 | MD, 0.08; 95% CI -0.15 to 0.30; I^2^=NA | 2 (181)99 | MD, -0.15; 95% CI -0.79 to 0.49; I^2^=0%
Clinical Outcomes | HDL Cholesterol (mmol/l) | 8 (6,005)90, 93, 97, 99, 104, 109 | MD, 0.02; 95% CI 0.0 to 0.04; I^2^ =0% | 2 (401)106, 108 | MD, 0.03; 95% CI -0.84 to 0.9; I^2^=54% | 2 (181)99 | MD, 0.1; 95% CI -0.22 to 0.02; I^2^=0%
Clinical Outcomes | LDL Cholesterol (mmol/l) | 6 (5,824)90, 93, 97, 104, 109 | MD, 0.02; 95% CI -0.03 to 0.07; I^2^=0% | 2 (401)106, 108 | MD, 0.13; 95% CI -1.52 to 1.78; I^2^=75% | NA | NA
Clinical Outcomes | Triglycerides (mmol/l) | 9 (6,073)90, 93, 96, 97, 99, 104, 109 | MD, -0.16; 95% CI -0.41 to 0.09; I^2^=72% | 1 (167)106 | MD, -0.05; 95% CI -0.40 to 0.30; I^2^=NA | 2 (181)99 | MD, -0.36; 95% CI -0.99 to 0.27; I^2^=0%
Clinical Outcomes | Systolic Blood Pressure (mmHg) | 5 (5,895)90, 96, 98, 100, 104 | MD, -0.63; 95% CI -3.13 to 1.87; I^2^=19% | 2 (205)105, 106 | MD, 2.49; 95% CI -10.46 to 15.44; I^2^=0% | NA | NA
Clinical Outcomes | Diastolic Blood Pressure (mmHg) | 5 (5,895)90, 96, 98, 100, 104 | MD, -0.36; 95% CI -3.03 to 2.31; I^2^=54% | 2 (205)105, 106 | MD, 0.06; 95% CI -8.6 to 8.72; I^2^=0% | NA | NA
Clinical Outcomes | Depression Symptoms | 3 (4,982)90, 101, 104 | SMD, -0.00; 95% CI -0.08 to 0.08; I^2^=0% | NA | NA | NA | NA
Clinical Outcomes | Anxiety Symptoms | 3 (233)99, 101 | MD, -1.49; 95% CI -2.1 to -0.88; I^2^ =0% | NA | NA | 2 (181)99 | MD, -1.80; 95% CI -3.07 to -0.53; I^2^ =0%
Behavioral Outcomes | Change in Physical Activity - Duration/Intensity (Subjective [days/week]) | 1 (40)19 | MD, -1.06; 95% CI -1.82 to -0.31; I^2^ =NA | NA | NA | NA | NA
Behavioral Outcomes | Change in Physical Activity - Duration/Intensity (Objective) | 2 (46)23 | SMD, 1.24; 95% CI -12.99 to 15.47; I^2^=89% | NA | NA | NA | NA
Behavioral Outcomes | Change in Physical Activity – Fitness | 3 (102)91, 93, 109 | SMD, 0.55; 95% CI -0.92 to 2.02; I^2^=55% | NA | NA | NA | NA
Behavioral Outcomes | Change in Physical Activity – Strength | NA | NA | NA | NA | NA | NA
Behavioral Outcomes | Change in Dietary Intake – Energy Intake (kcal/day) | 7 (242)23, 93, 94, 98, 100, 101 | MD, -158.94; 95% CI -333.73 to 15.85; I^2^=38% | 1 (38)105 | MD, -70.00; 95% CI -847.59 to 707.59; I^2^=NA | NA | NA
Behavioral Outcomes | Change in Dietary Intake – Saturated Fat Intake (% of daily kcal) | 2 (74)93, 101 | MD, -1.40; 95% CI -10.64 to 7.84; I^2^=22% | 1 (38)105 | MD, 2.00; 95% CI -0.77 to 4.77; I^2^=NA | NA | NA
Behavioral Outcomes | Adherence to Medication | 4 (1,309)15, 90, 95 | SMD, -0.05; 95% CI -0.17 to 0.07; I^2^=0% | NA | NA | NA | NA
Health Outcomes | Quality of Life – SF-36 Physical (higher score desirable) | 2 (4,432)96, 104 | MD, 5.00; 95% CI -50.92 to 60.92; I^2^=85% | 1 (167)106 | MD, 1.60; 95% CI -1.18 to 4.38; I^2^=NA | NA | NA
Health Outcomes | Quality of Life – SF-36 Mental (higher score desirable) | 2 (4,432)96, 104 | MD, -2.59; 95% CI -48.65 to 43.47; I^2^=74% | 1 (167)106 | MD, -1.00; 95% CI -3.82 to 1.82; I^2^=NA | NA | NA
Health Outcomes | Quality of Life – Other (lower score desirable) | 2 (767)90, 99 | SMD, -0.08; 95% CI -0.47 to 0.31; I^2^=11% | NA | NA | 2 (181)99 | SMD, -0.06; 95% CI -0.57 to 0.45; I^2^=0%
Health Outcomes | Diabetes-specific Quality of Life – Diabetes Distress (PAID) | NA | NA | 1 (167)106 | MD, 1.10; 95% CI -2.08 to 4.28; I^2^=NA | NA | NA
Health Outcomes | Diabetes-specific Quality of Life – Other (lower score desirable) | 4 (1,309)15, 90, 95 | SMD, 0.04; 95% CI -0.16 to 0.24; I^2^=17% | NA | NA | NA | NA
Health Outcomes | Mortality – All cause (longest followup) | 5 (6,050)90, 102, 104 | RR, 0.86; 95% CI, 0.77 to 0.96; I^2^ =0% | NA | NA | NA | NA
Program Acceptability | Participant Attrition | 21 (7,603)15, 19, 59, 90-92, 94, 96, 98-107 | RR, 0.87; 95% CI 0.78 to 0.97; I^2^ =0%

BMI = body mass index; CI = confidence interval; EOI = end of intervention; HbA_1c_ = hemoglobin A_1c_; I^2^ = statistical heterogeneity; kg = kilograms; m = month; MD = mean difference; NA = not applicable; RR = risk ratio; SMD = standardized mean difference

Table I3 Comparative effectiveness of behavioral programs for type 2 diabetes mellitus

Outcome | Category of Comparative Effectiveness | # Trials (# Subjects) | Study Effect at Longest Followup | Conclusion
HbA_1c_ | Addition of Support to DSME | 3 (387)102, 110, 111 | MD, -0.07; 95% CI -0.35 to 0.22 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
HbA_1c_ | Addition of Support to Lifestyle Program | 1 (114)20 | MD, 0.20; 95% CI -0.94 to 1.34 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
HbA_1c_ | Addition of Another Component to DSME | 4 (547)95, 112-114 | MD, 0.86; 95% CI -0.03 to 1.76 | No difference when adding care coordination,112 PST,95 MT,113 or PA114 to DSME 95, 113 or DSME + Support112, 114
HbA_1c_ | Addition of Another Component to Lifestyle Program | 3 (241)115-117 | MD, -0.05; 95% CI -0.34 to 0.25 | No difference when adding MI116, 117 or blood glucose regulation115 interventions to a lifestyle program
HbA_1c_ | High vs. Low Intensity | 2 (209)118, 119 | MD, -0.41; 95% CI -1.22 to 0.41 | No difference between high and low intensity DSME and support programs
HbA_1c_ | Delivery of DSME via technology vs. in person | 2 (126)120, 121 | MD, 0.07; 95% CI -0.61 to 0.75 | No difference when delivery of empowerment DSME with CST via telemedicine vs. in person at clinic,120 or when social-cognitive theory-guided group DSME for African Americans delivered via virtual world online vs in person121
HbA_1c_ | Delivery of DSME to groups vs. individuals | 3 (701)78, 99, 122 | MD, -0.36; 95% CI -0.63 to -0.08 | Improved using group compared with individual delivery of DSME
HbA_1c_ | Delivery by Peers vs. HCP | 4 (575)110, 111, 123, 124 | MD, 0.00; 95% CI -0.23 to 0.23 | No difference when delivery of DSME110, 123 or support phase111, 124 by peer compared with HCP
HbA_1c_ | Delivery by non-HCPs vs. HCP | 1 (72)111 | MD, 0.02; 95% CI -0.60 to 0.64 | No difference when support after DSME is provided by clinic staff vs. DM educators
HbA_1c_ | Addition of peers to CHW-led DSME + Support | 1 (116)125 | MD, -0.30; 95% CI -0.90 to 0.30 | No difference when adding peer leaders to support phase of CHW-led DSME + Support (Partners in Care)
HbA_1c_ | Others | 1 (99)126 | MD, -0.30; 95% CI -0.72 to 0.12 | No difference between CBT-based lifestyle program with portion-controlled diet and DSME with meal plan
HbA_1c_ | Others | 1 (600)127 | MD, -0.07; 95% CI -0.22 to 0.08 | No difference between DSME using PRECEDE model vs. conventional health promotion model
HbA_1c_ | Others | 1 (24)51 | MD, 0.19; 95% CI -0.76 to 1.14 | No difference between DSME with problem-solving approach using telephone delivery to couples vs. individuals
HbA_1c_ | Others | 1 (21)128 | MD, 0.13; 95% CI -1.18 to 1.44 | No difference between group-based culturally tailored DSME to individual DSME for rural African Americans
HbA_1c_ | Others | 1 (143)129 | MD, -0.30; 95% CI -0.58 to -0.02 | Improved with individual DSME with MI vs. group-based empowerment DSME with supervised group exercise
Change in Body Composition (BMI) | Addition of Support to DSME | 2 (259)110, 111 | MD, -0.08; 95% CI -0.58 to 0.41 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
Change in Body Composition (BMI) | Addition of Another Component to DSME | 3 (255)112-114 | MD, 0.08; 95% CI -0.48 to 0.64 | No difference when adding care coordination,112 MT,113 or PA114 to DSME or DSME + Support
Change in Body Composition (BMI) | Delivery of DSME to groups vs. individuals | 2 (212)99, 122 | MD, 0.16; 95% CI -1.12 to 1.44 | No difference using group delivery compared with individual delivery of DSME
Change in Body Composition (BMI) | Delivery by Peers vs. HCP | 2 (263)110, 111 | MD, 0.47; 95% CI -0.32 to 1.26 | No difference when delivery of DSME110 or support phase111 by peer compared with HCP
Change in Body Composition (BMI) | Delivery by non-HCPs vs. HCP | 1 (73)111 | MD, 0.31; 95% CI -0.72 to 1.34 | No difference when support after DSME is provided by clinic staff vs. DM educators111
Change in Body Composition (BMI) | Addition of peers to CHW-led DSME + Support | 1 (116)125 | MD, 0.50; 95% CI -0.24 to 1.24 | No difference when adding peer leaders to support phase of CHW-led DSME + Support (Partners in Care)
Change in Body Composition (BMI) | Other | 1 (99)126 | MD, -1.80; 95% CI -2.51 to -1.09 | Improved with CBT-based lifestyle program with portion-controlled diet compared with DSME with meal plan
Change in Body Composition (BMI) | Other | 1 (600)127 | MD, 0.06; 95% CI -0.19 to 0.31 | No difference between DSME using PRECEDE model vs. conventional health promotion model
Change in Body Composition (BMI) | Other | 1 (24)51 | MD, -0.04; 95% CI -5.27 to 5.19 | No difference between DSME with problem-solving approach using telephone delivery to couples vs. individuals
Change in Body Composition (Weight [kg]) | Addition of Support to Lifestyle Program | 1 (112)20 | MD, 0.41; 95% CI -7.21 to 8.03 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
Change in Body Composition (Weight [kg]) | Addition of Another Component to Lifestyle Program | 3 (241)115-117 | MD, -1.14; 95% CI -2.80 to 0.52 | No difference when adding MI116, 117 or blood glucose regulation115 interventions to a lifestyle program
Change in Body Composition (Weight [kg]) | High vs. Low Intensity | 1 (96)85 | MD, -1.30; 95% CI -2.90 to 0.30 | No difference between high and low intensity lifestyle program tailored to medically underserved
Change in Body Composition (Weight [kg]) | Delivery of DSME to groups vs. individuals | 2 (581)78, 122 | MD, -0.15; 95% CI -0.87 to 0.58 | No difference using group compared with individual delivery of DSME
Change in Body Composition (Weight [kg]) | Other | 1 (99)78, 126 | MD, -5.10; 95% CI -7.22 to -2.98 | Improved with CBT-based lifestyle program with portion-controlled diet compared with DSME with meal plan
Change in Body Composition (Weight [kg]) | Other | 1 (121)129 | MD, -0.10; 95% CI -1.30 to 1.10 | No difference between individual DSME with MI and. group-based empowerment DSME with supervised group exercise
Change in Body Composition (waist circumference) | Addition of Another Component to DSME + Support | 1 (88)114 | MD -2.00; 95% CI -5.75 to 1.75 | No difference when adding PA to DSME + Support
Change in Body Composition (waist circumference) | Addition of peers to CHW-led DSME + Support | 1 (116)125 | MD, 0.25; 95% CI -2.44 to 2.95 | No difference when adding peer leaders to support phase of CHW-led DSME + Support (Partners in Care)
Change in Body Composition (waist circumference) | Others | 1 (99)126 | MD, -3.60; 95% CI -5.33 to -1.87 | Improved with CBT-based lifestyle program with portion-controlled diet compared with DSME with meal plan
Change in Body Composition (waist circumference) | | 1 (24)51 | MD, -1.22; 95% CI -10.32 to 7.88 | No difference between DSME with problem-solving approach using telephone delivery to couples vs. individuals
Change in Body Composition (waist circumference) | | 1 (121)129 | MD, -0.20; 95% CI -1.51 to 1.11 | No difference between individual DSME with MI and. group-based empowerment DSME with supervised group exercise
Change in Dietary Intake (kcal/d) | Addition of Support to Lifestyle Program | 1 (102)20 | MD, -65.00; 95% CI -195.23 to 65.23 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
Change in Dietary Intake (% saturated fat/kcal) | Addition of Support to Lifestyle Program | 1 (102)20 | MD, 0.14; 95% CI -0.25 to 0.53 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
Medication Adherence | Addition of Another Component to DSME | 1 (296)95 | SMD, 0.05; 95% CI -0.18 to 0.28 | No difference when adding PST to DSME
Change in Physical Activity – Intensity/Duration (subjective; days per week) | Delivery of DSME to groups vs. individuals | 1 (92)122 | MD, 1.30; 95% CI -0.70 to 0.90 | No difference in group compared with individual delivery of DSME
Change in Physical Activity – Intensity/Duration (subjective; days per week) | Delivery by non-HCPs vs. HCP | 1 (73)111 | MD, 0.56; 95% CI -1.11 to 1.80 | No difference when support after DSME is provided by clinic staff vs. DM educators
Change in Physical Activity – Intensity/Duration (subjective; days per week) | Others | 1 (121)129 | MD, 1.30; 95% CI 0.80 to 1.80 | Improved between individual DSME with MI and group-based empowerment DSME with supervised group exercise
Change in Physical Activity – Intensity/Duration (objective) | Addition of Support to Lifestyle Program | 1 (111)20 | SMD, 0.23; 95% CI -0.15 to 0.60 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
Change in Physical Activity – Fitness | Addition of Another Component to DSME + Support | 1 (88)114 | SMD, 0.62; 95% CI 0.19 to 1.05 | Improved when adding a PA component to DSME + Support
Quality of Life-Other | Delivery of DSME to groups vs. individuals | 1 (120)99 | SMD, -0.08; 95% CI -0.44 to 0.28 | No difference using group compared with individual delivery of DSME
Quality of Life – SF-36 Physical | Delivery of DSME to groups vs. individuals | 1 (92)122 | MD, -0.80; 95% CI -4.04 to 2.44 | No difference in group compared with individual delivery of DSME
Quality of Life – SF-36 Mental | Delivery by Peers vs. HCP | 1 (221)124 | MD, -0.20; 95% CI -2.21 to 1.81 | No difference when delivery of support phase by peer compared with HCP
Diabetes-related Quality of Life (higher score desirable) | Addition of Another Component to DSME | 1 (196)95 | MD, 0.14; 95% CI -0.09 to 0.37 | No difference when adding PST to DSME
Diabetes-related Quality of Life (higher score desirable) | Delivery by Peers vs. HCP | 1 (198)110 | SMD, 0.11; 95% CI -0.17 to 0.38 | No difference when delivery of DSME by peer compared with HCP
Diabetes-related Quality of Life (higher score desirable) | Delivery of DSME via telemedicine vs. in person | 1 (35)120 | SMD, -0.06; 95% CI -0.72 to 0.61 | No difference when delivery of empowerment DSME with CST via telemedicine vs. in person at clinic
Diabetes-related Quality of Life (higher score desirable) | Addition of Support to Lifestyle Program | 1 (119)20 | SMD, 0.04; 95% CI -0.32 to 0.40 | No difference when adding tailoring (African American women) and social support in community to clinic-based lifestyle program
Diabetes-related Quality of Life (higher score desirable) | Other | 1 (121)129 | SMD, 0.15; 95% CI -0.20 to 0.51 | Improved between individual DSME with MI and. group-based empowerment DSME with supervised group exercise
Diabetes Distress (lower score desirable) | Delivery of DSME via telemedicine vs. in person | 1 (31)120 | MD, 3.60; 95% CI -12.05 to 19.25 | No difference when delivery of empowerment DSME with CST via telemedicine vs. in person at clinic
Diabetes Distress (lower score desirable) | Delivery by non-HCPs vs. HCP | 1 (73)111 | MD, 2.40; 95% CI -5.65 to 10.45 | No difference when support after DSME is provided by clinic staff vs. DM educators
Diabetes Distress (lower score desirable) | Delivery by Peers vs. HCP | 1 (74)111 | MD, 24.70; 95% CI 15.02 to 34.38 | Increased distress with delivery of support phase by peers compared with HCP

BMI = body mass index; CBT = cognitive-behavioral theory; CHW = community health worker; CI = confidence interval; CST = coping skills therapy; DM = diabetes mellitus; EOI = end of intervention; HbA_1c_ = hemoglobin A_1c_; HCP = health care professional; m = month; MD = mean difference; MI = motivational interviewing; MT = music therapy; NA = not applicable; PA = physical activity; PST = problem-solving training; SMD = standardized mean difference

## References for Appendix I

1 Adachi M, Yamaoka K, Watanabe M, et al. (2013). Effects of lifestyle education program for type 2 diabetes patients in clinics: a cluster randomized controlled trial. BMC Public Health.
2 Agurs-Collins TD, Kumanyika SK, Ten Have TR, et al. (1997). A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care.
3 Anderson DR, Christison-Lagay J, Villagra V, et al. (2010). Managing the space between visits: a randomized trial of disease management for diabetes in a community health center. J Gen Intern Med.
4 Anderson RM, Funnell MM, Nwankwo R, et al. (2005). Evaluating a problem-based empowerment program for African Americans with diabetes: results of a randomized controlled trial. Ethn Dis.
5 Anderson RM, Funnell MM, Aikens JE, et al. (2009). Evaluating the efficacy of an empowerment-based self-management consultant intervention: results of a two-year randomized controlled trial. Ther Patient Educ.
6 Barratt R, Frost G, Millward DJ, et al. (2008). A randomised controlled trial investigating the effect of an intensive lifestyle intervention v. standard care in adults with type 2 diabetes immediately after initiating insulin therapy. Br J Nutr.
7 Bond GE, Burr R, Wolf FM, et al. (2007). The effects of a web-based intervention on the physical outcomes associated with diabetes among adults age 60 and older: a randomized trial. Diabetes Technol Ther.
8 Brown SA, Garcia AA, Kouzekanani K, et al. (2002). Culturally competent diabetes self-management education for Mexican Americans: the Starr county border health initiative. Diabetes Care.
9 Castejon AM, Calderon JL, Perez A, et al. (2013). A community-based pilot study of a diabetes pharmacist intervention in Latinos: impact on weight and hemoglobin a1c. J Health Care Poor Underserved.
10 Chan LS. (2012). Chronic disease self-management in Hong Kong Chinese older adults living in the community. Dissertation Abstracts International: Section B: The Sciences and Engineering.
11 Cramer JS, Sibley RF, Bartlett DP, et al. (2007). An adaptation of the diabetes prevention program for use with high-risk, minority patients with type 2 diabetes. Diabetes Educ.
12 Davis RM, Hitch AD, Salaam MM, et al. (2010). Telehealth improves diabetes self-management in an underserved community: diabetes telecare. Diabetes Care.
13 Frosch DL, Uy V, Ochoa S, et al. (2011). Evaluation of a behavior support intervention for patients with poorly controlled diabetes. Arch Intern Med.
14 Gagliardino JJ, Lapertosa S, Pfirter G, et al. (2013). Clinical, metabolic and psychological outcomes and treatment costs of a prospective randomized trial based on different educational strategies to improve diabetes care (PRODIACOR). Diabet Med.
15 Glasgow RE, Kurz D, King D, et al. (2012). Twelve-month outcomes of an internet-based diabetes self-management support program. Patient Educ Couns.
16 Glasgow RE, Strycker LA, King DK, et al. (2006). Robustness of a computer-assisted diabetes self-management intervention across patient characteristics, healthcare settings, and intervention staff. Am J Manag Care.
17 Glasgow RE, Nutting PA, Toobert DJ, et al. (2006). Effects of a brief computer-assisted diabetes self-management intervention on dietary, biological and quality-of-life outcomes. Chronic Illn.
18 Hawkins SY. (2010). Improving glycemic control in older adults using a videophone motivational diabetes self-management intervention. Res Theory Nurs Pract.
19 Huisman S, De Gucht V, Maes S, et al. (2009). Self-regulation and weight reduction in patients with type 2 diabetes: a pilot intervention study. Patient Educ Couns.
20 Keyserling TC, Samuel-Hodge CD, Ammerman AS, et al. (2002). A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care.
21 Kim MT, Han HR, Song HJ, et al. (2009). A community-based, culturally tailored behavioral intervention for Korean Americans with type 2 diabetes. Diabetes Educ.
22 Kim SH, Lee SJ, Kang ES, et al. (2006). Effects of lifestyle modification on metabolic parameters and carotid intima-media thickness in patients with type 2 diabetes mellitus. Metabolism.
23 Koo BK, Han KA, Ahn HJ, et al. (2010). The effects of total energy expenditure from all levels of physical activity vs. physical activity energy expenditure from moderate-to-vigorous activity on visceral fat and insulin sensitivity in obese type 2 diabetic women. Diabet Med.
24 Lujan J, Ostwald SK, Ortiz M. (2007). Promotora diabetes intervention for Mexican Americans. Diabetes Educ.
25 Moriyama M, Nakano M, Kuroe Y, et al. (2009). Efficacy of a self-management education program for people with type 2 diabetes: results of a 12 month trial. Jpn J Nurs Sci.
26 Murrock CJ, Higgins PA, Killion C. (2009). Dance and peer support to improve diabetes outcomes in African American women. Diabetes Educ.
27 Nishita C, Cardazone G, Uehara DL, et al. (2013). Empowered diabetes management: life coaching and pharmacist counseling for employed adults with diabetes. Health Educ Behav.
28 Palmas W, Findley SE, Mejia M, et al. (2014). Results of the Northern Manhattan Diabetes Community Outreach Project: a randomized trial studying a community health horker intervention to improve diabetes care in Hispanic adults. Diabetes Care.
29 Philis-Tsimikas A, Fortmann A, Lleva-Ocana L, et al. (2011). Peer-led diabetes education programs in high-risk Mexican Americans improve glycemic control compared with standard approaches: a Project Dulce promotora randomized trial. Diabetes Care.
30 Prezio EA, Cheng D, Balasubramanian BA, et al. (2013). Community diabetes education (CODE) for uninsured Mexican Americans: a randomized controlled trial of a culturally tailored diabetes education and management program led by a community health worker. Diabetes Res Clin Pract.
31 Ridgeway NA, Harvill DR, Harvill LM, et al. (1999). Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. South Med J.
32 Rock CL, Flatt SW, Pakiz B, et al. (2014). Weight loss, glycemic control, and cardiovascular disease risk factors in response to differential diet composition in a weight loss program in type 2 diabetes: a randomized controlled trial. Diabetes Care.
33 Rosal MC, Olendzki B, Reed GW, et al. (2005). Diabetes self-management among low-income Spanish-speaking patients: a pilot study. Ann Behav Med.
34 Rosal MC, Ockene IS, Restrepo A, et al. (2011). Randomized trial of a literacy-sensitive, culturally tailored diabetes self-management intervention for low-income Latinos: Latinos en control. Diabetes Care.
35 Rothschild SK, Martin MA, Swider SM, et al. (2014). Mexican american trial of community health workers: a randomized controlled trial of a community health worker intervention for Mexican Americans with type 2 diabetes mellitus. Am J Public Health.
36 Ruggiero L, Moadsiri A, Butler P, et al. (2010). Supporting diabetes self-care in underserved populations: a randomized pilot study using medical assistant coaches. Diabetes Educ.
37 Ruggiero L, Riley BB, Hernandez R, et al. (2014). Medical assistant coaching to support diabetes self-care among low-income racial/ethnic minority populations: randomized controlled trial. West J Nurs Res.
38 Sacco WP, Malone JI, Morrison AD, et al. (2009). Effect of a brief, regular telephone intervention by paraprofessionals for type 2 diabetes. J Behav Med.
39 Samuel-Hodge CD, Keyserling TC, Park S, et al. (2009). A randomized trial of a church-based diabetes self-management program for African Americans with type 2 diabetes. Diabetes Educ.
40 Sarkadi A, Rosenqvist U. (2004). Experience-based group education in type 2 diabetes: a randomised controlled trial. Patient Educ Couns.
41 Sevick MA, Korytkowski M, Stone RA, et al. (2012). Biophysiologic outcomes of the enhancing adherence in type 2 diabetes (ENHANCE) trial. J Acad Nutr Diet.
42 Shibayama T, Kobayashi K, Takano A, et al. (2007). Effectiveness of lifestyle counseling by certified expert nurse of Japan for non-insulin-treated diabetic outpatients: a 1-year randomized controlled trial. Diabetes Res Clin Pract.
43 Sigurdardottir AK, Benediktsson R, Jonsdottir H. (2009). Instruments to tailor care of people with type 2 diabetes. J Adv Nurs.
44 Sinclair KA, Makahi EK, Shea-Solatorio C, et al. (2013). Outcomes from a diabetes self-management intervention for native Hawaiians and Pacific people: partners in care. Ann Behav Med.
45 Sixta CS, Ostwald S. (2008). Texas-Mexico border intervention by promotores for patients with type 2 diabetes. Diabetes Educ.
46 Skelly AH, Carlson JR, Leeman J, et al. (2005). Symptom-focused management for African American women with type 2 diabetes: a pilot study. Appl Nurs Res.
47 Spencer MS, Rosland AM, Kieffer EC, et al. (2011). Effectiveness of a community health worker intervention among African American and Latino adults with type 2 diabetes: a randomized controlled trial. Am J Public Health.
48 Sung K, Bae S. (2012). Effects of a regular walking exercise program on behavioral and biochemical aspects in elderly people with type ii diabetes. Nurs Health Sci.
49 Toobert DJ, Glasgow RE, Strycker LA, et al. (2003). Biologic and quality-of-life outcomes from the Mediterranean lifestyle program: a randomized clinical trial. Diabetes Care.
50 Toobert DJ, Strycker LA, King DK, et al. (2011). Long-term outcomes from a multiple-risk-factor diabetes trial for Latinas: viva bien!. Transl Behav Med.
51 Trief P, Sandberg JG, Ploutz-Snyder R, et al. (2011). Promoting couples collaboration in type 2 diabetes: the diabetes support project pilot data. Fam Syst Health.
52 Walker EA, Shmukler C, Ullman R, et al. (2011). Results of a successful telephonic intervention to improve diabetes control in urban adults: a randomized trial. Diabetes Care.
53 Welschen LMC, Van Oppen P, Bot SDM, et al. (2013). Effects of a cognitive behavioural treatment in patients with type 2 diabetes when added to managed care: a randomised controlled trial. J Behav Med.
54 Wolever RQ, Dreusicke M, Fikkan J, et al. (2010). Integrative health coaching for patients with type 2 diabetes: a randomized clinical trial. Diabetes Educ.
55 Wolf AM, Conaway MR, Crowther JQ, et al. (2004). Translating lifestyle intervention to practice in obese patients with type 2 diabetes: improving control with activity and nutrition (ICAN) study. Diabetes Care.
56 Yoo JS, Lee SJ, Lee HC, et al. (2007). The effect of a comprehensive lifestyle modification program on glycemic control and body composition in patients with type 2 diabetes. Asian Nurs Res.
57 Chlebowy DO, El-Mallakh P, Myers J, et al. (2014). Motivational interviewing to improve diabetes outcomes in African Americans adults with diabetes. West J Nurs Res.
58 Edelman D, Dolor RJ, Coffman CJ, et al. (2015). Nurse-led behavioral management of diabetes and hypertension in community practices: a randomized trial. J Gen Intern Med.
59 Holmen H, Torbjornsen A, Wahl AK, et al. (2014). A mobile health intervention for self-management and lifestyle change for persons with type 2 diabetes, part 2: one-year results from the Norwegian randomized controlled trial renewing health. JMIR MHealth and UHealth.
60 Kim SH, Lee SH, Ahn KY, et al. (2014). Effect of lifestyle modification on serum chemerin concentration and its association with insulin sensitivity in overweight and obese adults with type 2 diabetes. Clin Endocrinol (Oxf).
61 Moncrieft AE. (2014). Randomized controlled trial of a behavioral weight loss intervention for primary prevention of renal decline in type 2 diabetics. Dissertation Abstracts International: Section B: The Sciences and Engineering.
62 Varney JE, Weiland TJ, Inder WJ, et al. (2014). Effect of hospital-based telephone coaching on glycaemic control and adherence to management guidelines in type 2 diabetes, a randomised controlled trial. Intern Med J.
63 Yuan C, Lai CW, Chan LW, et al. (2014). The effect of diabetes self-management education on body weight, glycemic control, and other metabolic markers in patients with type 2 diabetes mellitus. J Diabetes Res.
64 Adolfsson ET, Walker-Engstrom ML, Smide B, et al. (2007). Patient education in type 2 diabetes: a randomized controlled 1-year follow-up study. Diabetes Res Clin Pract.
65 Anderson RM, Funnell MM, Butler PM, et al. (1995). Patient empowerment. Results of a randomized controlled trial. Diabetes Care.
66 Anderson-Loftin W, Barnett S, Bunn P, et al. (2005). Soul food light: culturally competent diabetes education. Diabetes Educ.
67 Beverly EA, Fitzgerald SM, Brooks KM, et al. (2013). Impact of reinforcement of diabetes self-care on poorly controlled diabetes: a randomized controlled trial. Diabetes Educ.
68 Deakin TA, Cade JE, Williams R, et al. (2006). Structured patient education: the diabetes X-PERT programme makes a difference. Diabet Med.
69 Goudswaard AN, Stolk RP, Zuithoff NP, et al. (2004). Long-term effects of self-management education for patients with type 2 diabetes taking maximal oral hypoglycaemic therapy: a randomized trial in primary care. Diabet Med.
70 Holtrop JS, Hickner J, Dosh S, et al. (2002). “Sticking to it—diabetes mellitus”: a pilot study of an innovative behavior change program for women with type 2 diabetes. Am J Health Educ.
71 Lee A, Siu CF, Leung KT, et al. (2011). General practice and social service partnership for better clinical outcomes, patient self efficacy and lifestyle behaviours of diabetic care: randomised control trial of a chronic care model. Postgrad Med J.
72 Lorig K, Ritter PL, Laurent DD, et al. (2010). Online diabetes self-management program: a randomized study. Diabetes Care.
73 Lorig K, Ritter PL, Villa F, et al. (2008). Spanish diabetes self-management with and without automated telephone reinforcement: two randomized trials. Diabetes Care.
74 Lorig K, Ritter PL, Villa FJ, et al. (2009). Community-based peer-led diabetes self-management: a randomized trial. Diabetes Educ.
75 Reaney M, Zorzo EG, Golay A, et al. (2013). Impact of conversation map education tools versus regular care on diabetes-related knowledge of people with type 2 diabetes: a randomized, controlled study. Diabetes Spectr.
76 Steed L, Lankester J, Barnard M, et al. (2005). Evaluation of the UCL diabetes self-management programme (UCL-DSMP): a randomized controlled trial. J Health Psychol.
77 Vincent D, Pasvogel A, Barrera L. (2007). A feasibility study of a culturally tailored diabetes intervention for Mexican Americans. Biol Res Nurs.
78 Sperl-Hillen J, Beaton S, Fernandes O, et al. (2013). Are benefits from diabetes self-management education sustained?. Am J Manag Care.
79 Cooper H, Booth K, Gill G. (2008). A trial of empowerment-based education in type 2 diabetes-global rather than glycaemic benefits. Diabetes Res Clin Pract.
80 Tucker CM, Lopez MT, Campbell K, et al. (2014). The effects of a culturally sensitive, empowerment-focused, community-based health promotion program on health outcomes of adults with type 2 diabetes. J Health Care Poor Underserved.
81 Wierenga ME. (1994). Life-style modification for weight control to improve diabetes health status. Patient Educ Couns.
82 Clark M, Hampson SE, Avery L, et al. (2004). Effects of a tailored lifestyle self-management intervention in patients with type 2 diabetes. Br J Health Psychol.
83 Thoolen B, De Ridder D, Bensing J, et al. (2007). Effectiveness of a self-management intervention in patients with screen-detected type 2 diabetes. Diabetes Care.
84 Eakin EG, Winkler EA, Dunstan DW, et al. (2014). Living well with diabetes: 24-month outcomes from a randomized trial of telephone-delivered weight loss and physical activity intervention to improve glycemic control. Diabetes Care.
85 Mayer-Davis EJ, D'antonio AM, Smith SM, et al. (2004). Pounds Off with Empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health.
86 Sorkin DH, Mavandadi S, Rook KS, et al. (2014). Dyadic collaboration in shared health behavior change: the effects of a randomized trial to test a lifestyle intervention for high-risk Latinas. Health Psychol.
87 Amoako E, Skelly AH, Rossen EK. (2008). Outcomes of an intervention to reduce uncertainty among African American women with diabetes. West J Nurs Res.
88 Vazquez IM, Millen B, Bissett L, et al. (1998). Buena Alimentacion, Buena Salud: a preventive nutrition intervention in Caribbean Latinos with type 2 diabetes. Am J Health Promot.
89 Bradshaw BG, Richardson GE, Kumpfer K, et al. (2007). Determining the efficacy of a resiliency training approach in adults with type 2 diabetes. Diabetes Educ.
90 Chan JC, Sui Y, Oldenburg B, et al. (2014). Effects of telephone-based peer support in patients with type 2 diabetes mellitus receiving integrated care: a randomized clinical trial. JAMA Intern Med.
91 Dasgupta K, Grover SA, Da Costa D, et al. (2006). Impact of modified glucose target and exercise interventions on vascular risk factors. Diabetes Res Clin Pract.
92 D'eramo Melkus G, Chyun D, Vorderstrasse A, et al. (2010). The effect of a diabetes education, coping skills training, and care intervention on physiological and psychosocial outcomes in black women with type 2 diabetes. Biol Res Nurs.
93 Dunstan DW, Mori TA, Puddey IB, et al. (1997). The independent and combined effects of aerobic exercise and dietary fish intake on serum lipids and glycemic control in NIDDM. A randomized controlled study. Diabetes Care.
94 Dunstan DW, Daly RM, Owen N, et al. (2005). Home-based resistance training is not sufficient to maintain improved glycemic control following supervised training in older individuals with type 2 diabetes. Diabetes Care.
95 Fisher L, Hessler D, Glasgow RE, et al. (2013). Redeem: a pragmatic trial to reduce diabetes distress. Diabetes Care.
96 Foster GD, Borradaile KE, Vander Veur SS, et al. (2009). The effects of a commercially available weight loss program among obese patients with type 2 diabetes: a randomized study. Postgrad Med.
97 Giannopoulou I, Fernhall B, Carhart R, et al. (2005). Effects of diet and/or exercise on the adipocytokine and inflammatory cytokine levels of postmenopausal women with type 2 diabetes. Metabolism.
98 Johnson ST, Bell GJ, Mccargar LJ, et al. (2009). Improved cardiovascular health following a progressive walking and dietary intervention for type 2 diabetes. Diabetes Obes Metab.
99 Kulzer B, Hermanns N, Reinecker H, et al. (2007). Effects of self-management training in type 2 diabetes: a randomized, prospective trial. Diabet Med.
100 Lynch EB, Liebman R, Ventrelle J, et al. (2014). A self-management intervention for African Americans with comorbid diabetes and hypertension: a pilot randomized controlled trial. Prev Chronic Dis.
101 Miller CK, Kristeller JL, Headings A, et al. (2014). Comparison of a mindful eating intervention to a diabetes self-management intervention among adults with type 2 diabetes: a randomized controlled trial. Health Educ Behav.
102 Skelly AH, Carlson J, Leeman J, et al. (2009). Controlled trial of nursing interventions to improve health outcomes of older African American women with type 2 diabetes. Nurs Res.
103 Weinger K, Beverly EA, Lee Y, et al. (2011). The effect of a structured behavioral intervention on poorly controlled diabetes: a randomized controlled trial. Arch Intern Med.
104 Wing RR, Bolin P, Brancati FL, et al. (2013). Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. N Engl J Med.
105 Cheong SH, Mccargar LJ, Paty BW, et al. (2009). The first step first bite program: guidance to increase physical activity and daily intake of low-glycemic index foods. J Am Diet Assoc.
106 Hermanns N, Kulzer B, Maier B, et al. (2012). The effect of an education programme (MEDIAS 2 ICT) involving intensive insulin treatment for people with type 2 diabetes. Patient Educ Couns.
107 Hill-Briggs F, Lazo M, Peyrot M, et al. (2011). Effect of problem-solving-based diabetes self-management training on diabetes control in a low income patient sample. J Gen Intern Med.
108 McGowan P. (2011). The efficacy of diabetes patient education and self-management education in type 2 diabetes. Can.
109 Bozzetto L, Annuzzi G, Costabile G, et al. (2014). A CHO/fibre diet reduces and a MUFA diet increases postprandial lipaemia in type 2 diabetes: no supplementary effects of low-volume physical training. Acta Diabetol.
110 Gagliardino JJ, Arrechea V, Assad D, et al. (2013). Type 2 diabetes patients educated by other patients perform at least as well as patients trained by professionals. Diabetes Metab Res Rev.
111 Siminerio L, Ruppert KM, Gabbay RA. (2013). Who can provide diabetes self-management support in primary care? Findings from a randomized controlled trial. Diabetes Educ.
112 Brown SA, Garcia AA, Winter M, et al. (2011). Integrating education, group support, and case management for diabetic Hispanics. Ethn Dis.
113 Mandel SE, Davis BA, Secic M. (2013). Effects of music therapy and music-assisted relaxation and imagery on health-related outcomes in diabetes education: a feasibility study. Diabetes Educ.
114 Plotnikoff RC, Pickering MA, Glenn N, et al. (2011). The effects of a supplemental, theory-based physical activity counseling intervention for adults with type 2 diabetes. J Phys Act Health.
115 Muchmore DB, Springer J, Miller M. (1994). Self-monitoring of blood glucose in overweight type 2 diabetic patients. Acta Diabetol.
116 Smith DE, Heckemeyer CM, Kratt PP, et al. (1997). Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care.
117 West DS, Dilillo V, Bursac Z, et al. (2007). Motivational interviewing improves weight loss in women with type 2 diabetes. Diabetes Care.
118 Brown SA, Blozis SA, Kouzekanani K, et al. (2005). Dosage effects of diabetes self-management education for Mexican Americans: the Starr county border health initiative. Diabetes Care.
119 Hendricks LE, Hendricks RT. (2000). The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ.
120 Izquierdo RE, Knudson PE, Meyer S, et al. (2003). A comparison of diabetes education administered through telemedicine versus in person. Diabetes Care.
121 Rosal MC, Heyden R, Mejilla R, et al. (2014). A virtual world versus face-to-face intervention format to promote diabetes self-management among African American women: a pilot randomized clinical trial. JMIR Res Protoc.
122 Rickheim PL, Weaver TW, Flader JL, et al. (2002). Assessment of group versus individual diabetes education: a randomized study. Diabetes Care.
123 Baksi AK, Al-Mrayat M, Hogan D, et al. (2008). Peer advisers compared with specialist health professionals in delivering a training programme on self-management to people with diabetes: a randomized controlled trial. Diabet Med.
124 Zgibor J, Piatt G. (2013). Project seed: support, education and evaluation in diabetes.
125 Tang TS, Funnell M, Sinco B, et al. (2014). Comparative effectiveness of peer leaders and community health workers in diabetes self-management support: results of a randomized controlled trial. Diabetes Care.
126 Foster GD, Wadden TA, Lagrotte CA, et al. (2013). A randomized comparison of a commercially available portion-controlled weight-loss intervention with a diabetes self-management education program. Nutr Diabetes.
127 Salinero-Fort MA, Carrillo-De Santa Pau E, Arrieta-Blanco FJ, et al. (2011). Effectiveness of precede model for health education on changes and level of control of hba1c, blood pressure, lipids, and body mass index in patients with type 2 diabetes mellitus. BMC Public Health.
128 Utz SW, Williams IC, Jones R, et al. (2008). Culturally tailored intervention for rural African Americans with type 2 diabetes. Diabetes Educ.
129 Vadstrup ES, Frolich A, Perrild H, et al. (2011). Effect of a group-based rehabilitation programme on glycaemic control and cardiovascular risk factors in type 2 diabetes patients: the Copenhagen Type 2 Diabetes Rehabilitation Project. Patient Educ Couns.