# Appendix H Strength of Evidence Tables for Type 1 Diabetes Mellitus

Table H1 Behavioral programs compared with usual care: strength of evidence for Key Question 1

Outcome | # Trials (# Subjects); Tool if Applicable | Risk of Bias | Consistency | Directness | Precision | Reporting Bias | Findings and Direction of Effects | Strength of Evidence
HbA_1c_ (EOI) | 16 (1,155)1-16 | Medium | Inconsistent | Direct | Precise | Unsuspected | MD, -0.11; 95% CI -0.33 to 0.11 | Low
HbA_1c_ (6m) | 12 (1,463) 3, 5, 6, 15, 17-24 | Medium | Consistent | Direct | Precise | Unsuspected | MD, -0.31; 95% CI -0.47 to -0.15 Favors behavioral programs | Moderate
HbA_1c_ (12m) | 7 (1,333) 2, 15, 20-22, 24, 25 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.22; 95% CI -0.49 to 0.05 | Low
HbA_1c_ (>12m) | 4 (1,138)6, 21, 22, 25 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.40; 95% CI -0.92 to 0.12 (>12m, <24m) MD, -0.08; 95% CI -1.96 to 1.8 (≥24m) | Low
Adherence to diabetes self-management (EOI) | 4 (282);3, 5, 8, 18 SMBG 1(74);1 SDSCA 1 (54);15 DSMP | High | Consistent | Direct | Imprecise | Unsuspected | MD, 0.15; 95% CI -0.54 to 0.84 MD, 1.4 days; 95% CI 0.35 to 2.43 MD, 5.00; 95% CI 0.60 to 9.40 | Low
Adherence to diabetes self-management (6m) | 5 (252);3, 5, 17, 18, 23 SMBG 1 (244);6 SDSCA 2 (471);21, 22 DSMP | High | Consistent | Direct | Imprecise | Unsuspected | MD, 0.40; 95% CI -0.36 to 1.16 MD, -0.06; 95% CI -0.60 to 0.48 No difference (different summary measures) | Low
Adherence to diabetes self-management (12m) | 1 (54);15 DSMP 1 (180);25 skipping one or more doses in past month | High | Consistent | Direct | Imprecise | Unsuspected | MD, 4.00; 95% CI -1.69 to 9.69 OR, 0.82; 95% CI, 0.48 to 0.1.38 | Insufficient
Adherence to diabetes self-management (≥12m) | 1 (390); SMBG 1 (190);25 skipping one or more doses in past month | High | Inconsistent | Direct | Imprecise | Unsuspected | MD, -0.36; 95% CI -0.69 to -0.03 (≥24m) OR, 1.30; 95% CI, 0.78 to 2.17 (24m) | Insufficient
Change in body composition (BMI) (EOI)(6m) | 1 (60)4 | Medium | Unknown | Direct | Imprecise | Unsuspected | MD, 0.08; 95% CI, -0.35 to 0.51 | Insufficient
Change in body composition (BMI) | 1 (227)6 | High | Unknown | Direct | Imprecise | Unsuspected | MD, -0.21; 95% CI, -0.62 to 0.20 | Insufficient
Change in body composition (kg) | 1 (61)13 | High | Unknown | Direct | Imprecise | Unsuspected | MD, -0.50; 95% CI, -5.69 to 4.69 | Insufficient
Change in physical activity (fitness–VO_2_ max) (EOI) | 1 (43)13 | High | Unknown | Direct | Imprecise | Unsuspected | MD, 0.59; 95% CI 0.22 to 0.96 Favors behavioral programs | Insufficient
Change in physical activity (intensity/duration) (EOI) | 2 (91)1, 3 | High | Consistent | Direct | Imprecise | Unsuspected | SMD, 0.16; 95% CI -0.25 to 0.57 | Insufficient
Change in physical activity (intensity/duration) (6m) | 2 (272)3, 6 | High | Inconsistent | Direct | Imprecise | Unsuspected | SMD, -0.26; 95% CI -1.0 to 0.49 | Insufficient
Change in nutrient intake (kcal/day) (EOI) | 1 (61)13 | High | Unknown | Direct | Imprecise | Unsuspected | MD, -247.10; 95% CI -281.7 to -212.5 Favors behavioral programs | Insufficient
Change in nutrient intake (saturated fat) (EOI) | 1 (61)13 | High | Unknown | Direct | Imprecise | Unsuspected | MD, -1.80; 95% CI -3.53 to -0.07; favors behavioral programs | Insufficient
Generic HRQL (EOI) | 7 (474)1, 5, 7-9, 16, 26 | High | Consistent | Direct | Precise | Unsuspected | SMD, 0.10; 95% CI -0.18 to 0.38 | Moderate
Generic HRQL (6m) | 1 (53)5 | High | Unknown | Direct | Imprecise | Unsuspected | SMD, -0.29; 95% CI -0.83 to 0.26 | Insufficient
Generic HRQL (12m) | 2 (405)9, 25 | High | Unknown | Direct | Imprecise | Unsuspected | SMD, 0.02; 95% CI -0.11 to 0.15 | Insufficient
Generic HRQL (≥12m) | 1 (291)25 | High | Unknown | Direct | Imprecise | Unsuspected | SMD, -0.04; 95% CI -0.27 to 0.19 | Insufficient
Diabetes-specific quality of life (EOI) | 3 (212)11, 16, 26 | High | Inconsistent | Direct | Imprecise | Unsuspected | SMD, 0.08; 95% CI, -1.44 to 1.60 | Insufficient
Diabetes Distress (EOI) | 4 (209)1, 3, 5, 7 | High | Consistent | Direct | Imprecise | Unsuspected | SMD, -0.31; 95% CI, -0.83 to 0.21 | Low
Diabetes Distress (6m) | 4 (236)3, 5, 23, 24 | High | Consistent | Direct | Imprecise | Unsuspected | SMD, -0.28; 95% CI, -0.94 to 0.38 | Low

Note: No study reported on complications or all-cause mortality. Only clinical trials were included in strength of evidence assessments. Lower scores beneficial for HbA_1c_, Diabetes Distress, Change in Nutrient Intake, and Change in Body Composition; higher scores beneficial for Adherence to Diabetes Self-management, Change in Physical Activity, and Generic and Diabetes-specific Quality of Life.

CI = confidence interval; DSMP = Diabetes Self-Management Profile; EOI = end of intervention; HbA_1c_ = hemoglobin A_1c_; HRQL = health-related quality of life; M = month; MD = mean difference; SDSCA = Summary of Diabetes Self-Care Activities; SMBG = self-monitoring of blood glucose

Table H2 Behavioral programs compared with an active control: strength of evidence for Key Question 1

Outcome | # Trials (# Subjects); Tool if Applicable | Risk of Bias | Consistency | Directness | Precision | Reporting Bias | Findings and Direction of Effects | Strength of Evidence
HbA_1c_ (EOI) | 4 (529) 15, 27-29 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.32; 95% CI -0.97 to 0.33 | Low
HbA_1c_ (6m) | 4 (467)15, 28-30 | Medium | Consistent | Direct | Precise | Unsuspected | MD, -0.44; 95% CI -0.69 to -0.19 Favors behavioral programs | Moderate
HbA_1c_ (12m) | 3 (305)15, 28, 29 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.44; 95% CI -1.04 to 0.16 | Low
Adherence to diabetes self-management (EOI) | 1 (54);15 DSMP 1 (149);28 DBRS | High | Inconsistent | Direct | Imprecise | Unsuspected | MD, 2.40; 95% CI -2.46 to 7.26 No data reported; those in behavioral program did more poorly | Insufficient
Adherence to diabetes self-management (6m) | 1 (149);30 SMBG 1 (149);28 DBRS | High | Inconsistent | Direct | Imprecise | Unsuspected | MD, -0.20; 95% CI -0.76 to 0.36 No data reported; those in behavioral program did more poorly | Insufficient
Adherence to diabetes self-management (12m) | 1 (54);15 DSMP 1 (149);28 DBRS | High | Inconsistent | Direct | Imprecise | Unsuspected | MD, 2.00; 95% CI -3.78 to 7.78 No data reported; those in behavioral program did more poorly | Insufficient

Note: Only clinical trials were included in strength of evidence assessments. Lower scores beneficial for HbA_1c_; higher scores beneficial for adherence to diabetes self-management.

CI = confidence interval; DBRS = Diabetes Behavior Rating Scale; DSMP = Diabetes Self-Management Profile; EOI = end of intervention; HbA_1c_ = hemoglobin A_1c_; M = month; MD = mean difference; SDSCA = Summary of Diabetes Self-Care Activities; SMBG = self-monitoring of blood glucose

Table H3 Behavioral programs compared with usual care: strength of evidence for Key Question 2 (age subgroups)

Outcome | # Trials (# Subjects); Tool if Applicable | Risk of Bias | Consistency | Directness | Precision | Reporting Bias | Findings and Direction of Effects | Strength of Evidence
Youth
HbA_1c_ (EOI) | 11 (653)2-5, 8-10, 12, 14-16 | Medium | Inconsistent | Direct | Precise | Unsuspected | MD, 0.00; 95% CI -0.33 to 0.33 | Low
HbA_1c_ (6m) | 10 (1,213)3, 5, 15, 17-22, 24 | Medium | Consistent | Direct | Precise | Unsuspected | MD, -0.28; 95% CI -0.51 to -0.05 Favors behavioral programs | Moderate
HbA_1c_ (12m) | 7 (1,333)2, 15, 20-22, 24, 25 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.22; 95% CI -0.49 to 0.05 | Low
Adults
HbA_1c_ (EOI) | 5 (502)1, 6, 7, 11, 13 | High | Consistent | Direct | Imprecise | Unsuspected | MD, -0.28; 95% CI -0.57 to 0.01 | Low
HbA_1c_ (6m) | 2 (250)6, 23 | High | Consistent | Direct | Imprecise | Unsuspected | MD, -0.38; 95% CI -0.82 to 0.06 | Low
HbA_1c_ (12m) | NR | | | | | | | Insufficient

CI = confidence interval; EOI = end of intervention; HbA_1c_ = hemoglobin A_1c_; M = month; MD = mean difference

Table H4 Behavioral programs compared with active controls: strength of evidence for Key Question 2 (age subgroups)

Outcome | # Trials (# Subjects); Tool if Applicable | Risk of Bias | Consistency | Directness | Precision | Reporting Bias | Findings and Direction of Effects | Strength of Evidence
Youth
HbA_1c_ (EOI) | 3 (419)15, 27, 28 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.33; 95% CI -1.65 to 0.99 | Insufficient
HbA_1c_ (6m) | 2 (208)15, 28 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.60; 95% CI -2.56 to 1.36 | Insufficient
HbA_1c_ (12m) | 2 (195)15, 28 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.52; 95% CI -1.04 to 0.00 | Low
Adults
HbA_1c_ (EOI) | 1 (147)29 | Medium | Unknown | Direct | Imprecise | Unsuspected | MD, -0.35; 95% CI -0.81 to 0.11 | Insufficient
HbA_1c_ (6m) | 2 (259)29, 30 | Medium | Consistent | Direct | Imprecise | Unsuspected | MD, -0.38; 95% CI -0.93 to 0.17 | Low
HbA_1c_ (12m) | 1 (110)29 | Medium | Unknown | Direct | Imprecise | Unsuspected | MD, -0.14; 95% CI -0.61 to 0.33 | Insufficient

CI = confidence interval; EOI = end of intervention; HbA_1c_ = hemoglobin A_1c_; M = month; MD = mean difference

## References for Appendix H

1 Amsberg S, Anderbro T, Wredling R, et al. (2009). A cognitive behavior therapy-based intervention among poorly controlled adult type 1 diabetes patients-a randomized controlled trial. Patient Educ Couns.
2 Anderson BJ, Brackett J, Ho J, et al. (1999). An office-based intervention to maintain parent-adolescent teamwork in diabetes management. Impact on parent involvement, family conflict, and subsequent glycemic control. Diabetes Care.
3 Boardway RH, Delamater AM, Tomakowsky J, et al. (1993). Stress management training for adolescents with diabetes. J Pediatr Psychol.
4 Franklin VL, Waller A, Pagliari C, et al. (2006). A randomized controlled trial of sweet talk, a text-messaging system to support young people with diabetes. Diabet Med.
5 Husted GR, Thorsteinsson B, Esbensen BA, et al. (2014). Effect of guided self-determination youth intervention integrated into outpatient visits versus treatment as usual on glycemic control and life skills: a randomized clinical trial in adolescents with type 1 diabetes. Trials.
6 Ismail K, Thomas SM, Maissi E, et al. (2008). Motivational enhancement therapy with and without cognitive behavior therapy to treat type 1 diabetes: a randomized trial. Ann Intern Med.
7 Karlsen B, Idsoe T, Dirdal I, et al. (2004). Effects of a group-based counselling programme on diabetes-related stress, coping, psychological well-being and metabolic control in adults with type 1 or type 2 diabetes. Patient Educ Couns.
8 Katz ML, Volkening LK, Butler DA, et al. (2014). Family-based psychoeducation and care ambassador intervention to improve glycemic control in youth with type 1 diabetes: a randomized trial. Pediatr Diabetes.
9 Laffel LM, Vangsness L, Connell A, et al. (2003). Impact of ambulatory, family-focused teamwork intervention on glycemic control in youth with type 1 diabetes. J Pediatr.
10 Lehmkuhl HD, Storch EA, Cammarata C, et al. (2010). Telehealth behavior therapy for the management of type 1 diabetes in adolescents. J Diabetes Sci Technol.
11 Mannucci E, Pala L, Rotella CM. (2005). Long-term interactive group education for type 1 diabetic patients. Acta Diabetol.
12 Murphy HR, Wadham C, Rayman G, et al. (2007). Approaches to integrating paediatric diabetes care and structured education: experiences from the families, adolescents, and children's teamwork study (FACTS). Diabet Med.
13 Perry TL, Mann JI, Lewis-Barned NJ, et al. (1997). Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). Eur J Clin Nutr.
14 Viklund G, Ortqvist E, Wikblad K. (2007). Assessment of an empowerment education programme: a randomized study in teenagers with diabetes. Diabet Med.
15 Wysocki T, Harris MA, Buckloh LM, et al. (2007). Randomized trial of behavioral family systems therapy for diabetes: maintenance of effects on diabetes outcomes in adolescents. Diabetes Care.
16 Mayer-Davis EJ, Seid M, Crandell J, et al. (2014). Flexible lifestyles for youth (fl3x) behavioural intervention for at-risk adolescents with type 1 diabetes: a randomized pilot and feasibility trial. Diabet Med.
17 Cook S, Herold K, Edidin DV, et al. (2002). Increasing problem solving in adolescents with type 1 diabetes: the choices diabetes program. Diabetes Educ.
18 Ellis DA, Templin T, Naar-King S, et al. (2007). Multisystemic therapy for adolescents with poorly controlled type i diabetes: stability of treatment effects in a randomized controlled trial. J Consult Clin Psychol.
19 Mcnabb WL, Quinn MT, Murphy DM, et al. (1994). Increasing children's responsibility for diabetes self-care: the in control study. Diabetes Educ.
20 Murphy HR, Wadham C, Hassler-Hurst J, et al. (2012). Randomized trial of a diabetes self-management education and family teamwork intervention in adolescents with type 1 diabetes. Diabet Med.
21 Nansel TR, Iannotti RJ, Simons-Morton BG, et al. (2007). Diabetes personal trainer outcomes: short-term and 1-year outcomes of a diabetes personal trainer intervention among youth with type 1 diabetes. Diabetes Care.
22 Nansel TR, Iannotti RJ, Liu A. (2012). Clinic-integrated behavioral intervention for families of youth with type 1 diabetes: randomized clinical trial. Pediatrics.
23 Zoffmann V, Lauritzen T. (2006). Guided self-determination improves life skills with type 1 diabetes and a1c in randomized controlled trial. Patient Educ Couns.
24 Serlachius AS, Scratch SE, Northam EA, et al. (2014). A randomized controlled trial of cognitive behaviour therapy to improve glycaemic control and psychosocial wellbeing in adolescents with type 1 diabetes. J Health Psychol.
25 Christie D, Thompson R, Sawtell M, et al. (2014). Structured, intensive education maximising engagement, motivation and long-term change for children and young people with diabetes: a cluster randomised controlled trial with integral process and economic evaluation - the cascade study. Health Technol Assess.
26 Kichler JC, Kaugars AS, Marik P, et al. (2013). Effectiveness of groups for adolescents with type 1 diabetes mellitus and their parents. Fam Syst Health.
27 Ellis DA, Naar-King S, Chen X, et al. (2012). Multisystemic therapy compared to telephone support for youth with poorly controlled diabetes: findings from a randomized controlled trial. Ann Behav Med.
28 Holmes CS, Chen R, Mackey E, et al. (2014). Randomized clinical trial of clinic-integrated, low-intensity treatment to prevent deterioration of disease care in adolescents with type 1 diabetes. Diabetes Care.
29 Weinger K, Beverly EA, Lee Y, et al. (2011). The effect of a structured behavioral intervention on poorly controlled diabetes: a randomized controlled trial. Arch Intern Med.
30 Hermanns N, Kulzer B, Ehrmann D, et al. (2013). The effect of a diabetes education programme (PRIMAS) for people with type 1 diabetes: results of a randomized trial. Diabetes Res Clin Pract.