# Appendix G Type 1 Diabetes Mellitus: Summary of Results From Observational Studies

Table G1 Summary of results from observational studies

Study, Year (# Subjects) | Outcome | Timepoint | Results | Conclusion
Thomas-Dobersen, 1993 (20 youth) | HbA_1c_ | EOI | MD, -0.50; 95% CI -1.84 to 0.84 | No difference
Thomas-Dobersen, 1993 (20 youth) | HbA_1c_ | 12m followup | MD, 0.67; 95% CI -1.47 to 2.81 | No difference
Thomas-Dobersen, 1993 (20 youth) | Depression | EOI | SMD, -.43; 95% CI -0.84 to 0.75 | No difference
Thomas-Dobersen, 1993 (20 youth) | Depression | 12m followup | SMD, 0.05; 95% CI -0.86 to 0.96 | No difference
Thomas-Dobersen, 1993 (20 youth) | BMI | EOI | MD, 0.29; 95% CI -1.06 to 0.48 | No difference
Thomas-Dobersen, 1993 (20 youth) | | 12m followup | MD, -0.27; 95% CI -1.87 to 1.36 | No difference
Thomas-Dobersen, 1993 (20 youth) | Weight | EOI | MD, -1.13; 95% CI -2.72 to 0.46 | No difference
Thomas-Dobersen, 1993 (20 youth) | | 12m followup | MD, -0.40; 95% CI -4.54 to 3.74 | No difference
Thomas-Dobersen, 1993 (20 youth) | Participant attrition | 12m | RR, 1.64; 95% CI 0.16, 2.46 | Increased risk of attrition for those receiving usual care
Viner, 2003 (41 youth) | HbA_1c_ | 12m followup | MD, -1.20; 95% CI -2.24 to -0.16 | Improved for those receiving behavioral program
Forlani, 2006 (90 adults) | HbA_1c_ | 12m followup | MD, -0.70; 95% CI -1.31 to -0.09 | Improved for those receiving behavioral program
Forlani, 2006 (90 adults) | HRQL | 12m followup | SMD, 0.31; 95% CI -0.11 to 0.74 | No difference
Forlani, 2006 (90 adults) | HRQL-diabetes specific | 12m followup | SMD, 0.03; 95% CI -0.39 to 0.45 | No difference

BMI = body mass index; EOI = end of intervention; m = month; MD = mean difference; QOL = quality of life; RR = risk ratio; SMD = standardized mean difference

1 Thomas-Dobersen DA, Butler-Simon N, Fleshner M. (1993). Evaluation of a weight management intervention program in adolescents with insulin-dependent diabetes mellitus. J Am Diet Assoc.
2 Viner RM, Christie D, Taylor V, et al. (2003). Motivational/solution-focused intervention improves HbA1c in adolescents with type 1 diabetes: A pilot study. Diabet Med.
3 Forlani G, Zannoni C, Tarrini G, et al. (2006). An empowerment-based educational program improves psychological well-being and health-related quality of life in type 1 diabetes. J Endocrinol Invest.