# Appendix F Description of Studies and Interventions

Table F1 Description of studies and interventions for T1DM in youth

Table F2 Description of studies and interventions for T1DM in adults

Table F3 Description of studies and interventions for T2DM