# Appendix E Risk of Bias

Table E1 Risk of bias for studies on type 1 diabetes mellitus

Author, Year | SG | AC | Blinding of PP Subjective Objective | | Blinding of OA Subjective Objective | | IOD Subjective Objective | | SOR | Other | Overall Subjective Objective
Amsberg, 2009 | M | M | H | M | H | L | H | H | L | L | H | H
Anderson, 1999 | M | M | NA^*^ | M | NA | L | NA | L | L | L | NA | M
Boardway, 1993 | M | M | H | M | H | L | H | H | L | L | H | H
Christie, 2014 | L | L | H | M | H | L | H | M | L | L | H | M
Cook, 2002 | M | M | H | M | H | L | H | H | L | L | H | H
Ellis, 2007 | M | M | NA | M | NA | L | NA | M | L | L | NA | M
Ellis, 2012 | L | M | M | M | M | L | M | M | M | L | M | M
Franklin, 2006 | L | M | H | M | H | L | M | M | L | L | H | M
Freeman, 2013 | M | M | M | M | M | L | H | H | L | L | H | H
Hermanns, 2013 | L | L | H | M | H | L | L | L | L | L | H | M
Holmes, 2014 | M | M | NA | M | NA | L | NA | N | L | L | NA | H
Husted, 2014 | L | L | H | M | H | L | H | H | L | H | H | H
Ismail, 2008 | L | H | H | M | H | L | H | M | M | H | H | H
Karlsen, 2004 | M | M | H | M | H | L | H | H | L | L | H | H
Katz, 2014 | M | M | H | M | H | L | L | L | L | L | H | M
Kichler, 2013 | M | M | H | M | H | L | H | M | L | L | H | M
Laffel, 2003 | M | M | H | M | H | L | L | L | L | L | H | M
Lehmkuhl, 2010 | L | M | NA | M | NA | L | NA | H | L | L | NA | H
Mannucci, 2005 | H | H | H | M | H | L | H | H | L | H | H | H
Mayer-Davis, 2014 | L | M | H | M | H | L | L | L | L | L | H | M
McNabb, 1994 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Murphy, 2007 | M | M | NA | M | NA | L | NA | M | M | L | NA | M
Murphy, 2012 | L | L | NA | M | NA | L | NA | L | M | L | NA | M
Nansel, 2007 | L | M | H | M | H | L | L | L | L | L | H | M
Nansel, 2012 | L | M | H | M | H | L | L | L | L | L | H | M
Perry, 1997 | M | M | H | M | H | L | H | H | L | L | H | H
Serlachius, 2014 | L | M | H | M | H | L | H | L | L | M | H | M
Viklund, 2007 | M | M | NA | M | NA | L | NA | L | L | L | NA | M
Weinger, 2011 | L | M | NA | M | NA | L | NA | L | L | L | NA | M
Wysocki, 2007 | M | M | H | M | H | L | M | M | L | L | H | M
Zoffmann, 2006 | H | L | H | M | H | L | H | H | L | L | H | H

* These trials may have reported on subjective (i.e., patient reported) outcomes but they were either not of interest to the review or not included in the analysis because of lacking data.

AC = allocation concealment; Blinding of OA = blinding of outcome assessors; Blinding of PP = blinding of participants and personnel; H = high risk of bias; IOD = incomplete outcome data; L = low risk of bias; M = medium or unclear risk of bias; NA = not applicable; Other = other sources of bias; Overall = overall risk of bias assessment; SG = sequence generation; SOR = selective outcome reporting

Table E2 Risk of bias for studies on type 2 diabetes mellitus

Author, Year | SG | AC | Blinding of PP Subjective Objective | | Blinding of OA Subjective Objective | | IOD Subjective Objective | | SOR | Other | Overall Subjective Objective
Adachi, 2013 | M | M | H | M | H | L | M | M | L | L | H | M
Adolfsson, 2007 | M | L | NA^*^ | M | NA | L | NA | H | L | H | NA | H
Agur-Collins, 1997 | M | M | H | M | H | L | H | H | L | L | H | H
Amoako, 2008 | H | H | H | M | H | L | M | M | L | L | H | H
Anderson, 1995 | M | M | H | M | H | L | H | H | L | L | H | H
Anderson, 2005 | M | M | H | M | H | L | L | L | L | L | H | M
Anderson, 2009 | L | L | H | M | H | L | H | H | L | L | H | H
Anderson, 2010 | M | M | NA | M | NA | L | NA | H | L | H | NA | H
Anderson-Loftin, 2005 | L | M | H | M | H | L | H | H | L | L | H | H
Baksi, 2008 | L | M | NA | M | NA | L | NA | H | L | L | NA | H
Barratt, 2008 | L | M | NA | M | NA | L | NA | L | L | L | NA | M
Beverly, 2013 | L | M | M | M | M | L | H | H | L | M | H | H
Bond, 2007 | M | M | H | M | H | L | L | L | L | L | H | M
Bozzetto, 2014 | L | M | M | M | M | L | H | H | L | L | H | H
Bradshaw, 2007 | M | M | M | M | M | L | H | H | M | L | H | H
Brown, 2002 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Brown, 2005 | M | M | M | M | M | L | L | L | L | L | M | M
Brown, 2011 | M | M | NA | M | NA | L | NA | L | L | L | NA | M
Castejon, 2013 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Chan, 2012 | L | M | H | M | H | L | H | H | L | L | H | H
Chan, 2014 | L | L | M | M | M | L | L | L | L | L | M | M
Cheong, 2009 | M | M | M | M | M | L | H | H | L | L | H | H
Chlebowy, 2014 | M | M | H | M | H | L | H | H | L | L | H | H
Clark, 2004 | L | M | H | M | H | L | L | L | L | L | H | M
Cooper, 2008 | M | M | NA | M | NA | L | NA | H | H | M | NA | H
Corkery, 1997 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Cramer, 2007 | M | M | H | M | H | L | H | H | L | M | H | H
Dasgupta, 2006 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Davis, 2010 | M | M | NA | M | NA | L | NA | M | L | L | NA | M
Deakin, 2006 | M | M | H | M | H | L | L | L | L | L | H | M
D-Eramo Melkus, 2010 | L | M | M | M | M | L | M | M | L | L | M | M
Dunstan, 1997 | M | M | H | M | H | L | H | H | L | L | H | H
Dunstan, 2005 | M | M | M | M | M | L | H | H | L | L | H | H
Eakin, 2014 | L | M | H | M | H | L | M | M | L | L | H | M
Edelman, 2015 | M | M | NA | M | NA | L | NA | M | L | L | NA | M
Fisher, 2013 | L | M | M | M | H | L | H | H | M | L | H | H
Foster, 2009 | L | M | H | M | H | L | L | L | L | L | H | M
Foster, 2013 | L | M | NA | M | NA | L | NA | L | L | L | NA | M
Frosch, 2011 | M | M | H | M | H | L | H | H | L | L | H | H
Gagliardino, 2013a | M | M | M | M | M | L | L | L | L | L | M | M
Gagliardino, 2013b | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Giannopoulou, 2005 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Glasgow, 2006a | M | M | H | M | H | L | M | M | L | L | H | M
Glasgow, 2006b | L | M | H | M | H | L | H | H | L | L | H | H
Glasgow, 2012 | L | M | H | M | H | L | M | M | L | L | H | M
Goudswaard, 2004 | L | M | NA | M | NA | L | NA | H | L | L | NA | H
Hawkins, 2010 | L | L | NA | M | NA | L | NA | H | L | L | NA | H
Hendricks, 2000 | M | M | M | M | M | L | H | H | L | L | H | H
Hermanns, 2012 | L | M | M | M | M | L | H | H | L | L | H | H
Hill-Briggs, 2011 | M | M | NA | M | NA | L | NA | L | L | L | NA | M
Holmen, 2014 | L | M | H | M | H | L | M | M | L | M | H | M
Holtrop, 2002 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Huisman, 2009 | M | M | H | M | H | L | H | H | L | L | H | H
Izquierdo, 2003 | M | M | M | M | M | L | H | H | L | H | H | H
Johnson, 2009 | L | M | M | M | M | L | M | M | L | L | M | M
Jones, 2003 | M | M | NA | M | NA | L | NA | M | L | L | NA | M
Keyserling, 2002 | L | M | M | M | H | L | H | H | L | H | H | H
Kim, 2006 | M | M | NA | M | NA | L | NA | L | L | L | NA | M
Kim, 2009 | L | M | H | M | H | L | L | L | L | L | H | M
Kim, 2014 | M | M | H | M | H | L | H | H | L | L | H | H
Koo, 2010 | M | M | NA | M | NA | L | NA | M | L | L | NA | M
Kulzer, 2007 | M | M | H | M | H | L | M | M | L | L | H | M
Lee, 2011 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Lorig, 2008 | M | M | H | M | H | L | H | H | L | L | H | H
Lorig, 2009 | L | M | H | M | H | L | M | M | L | L | H | M
Lorig, 2010 | L | M | H | M | H | L | M | M | L | L | H | M
Lujan, 2007 | M | M | NA | M | NA | L | NA | L | L | L | NA | M
Lynch, 2014 | M | M | M | M | M | L | H | H | L | H | H | H
Mandel, 2013 | L | L | M | M | M | L | H | H | L | L | H | H
Mayer-Davis, 2004 | M | M | NA | M | NA | L | NA | M | L | L | NA | M
McGowan, 2011 | H | L | M | M | M | L | H | H | L | L | H | H
Miller, 2014 | L | M | M | M | M | L | H | H | L | L | H | H
Moncrieft, 2014 | M | M | H | M | H | L | M | M | L | M | H | M
Moriyama, 2009 | H | H | H | M | H | L | H | H | L | L | H | H
Muchmore, 1994 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Murrock, 2009 | L | M | NA | M | NA | L | NA | H | L | L | NA | H
Nashita, 2013 | M | M | H | M | H | L | H | H | L | L | H | H
Palmas, 2014 | L | L | NA | M | NA | L | NA | M | L | L | NA | M
Philis-Tsimikas, 2011 | L | H | NA | M | NA | L | NA | H | L | L | NA | H
Plotnikoff, 2011 | L | M | M | M | M | L | M | M | L | L | M | M
Prezio, 2013 | L | M | NA | M | NA | L | NA | M | L | L | NA | M
Reaney, 2013 | L | M | H | M | H | L | L | M | L | L | H | M
Rickheim, 2002 | H | H | H | M | H | L | H | H | L | H | H | H
Ridgeway, 1999 | M | M | H | M | H | L | H | H | M | L | H | H
Rock, 2014 | L | M | H | M | H | L | M | M | L | L | H | M
Rosal, 2005 | M | M | H | M | H | L | L | L | L | L | H | M
Rosal, 2011 | M | M | H | M | H | L | M | M | L | M | H | M
Rosal, 2014 | L | M | M | M | M | L | L | L | L | H | H | H
Rothschild, 2014 | L | M | L | L | L | L | M | M | L | H | H | H
Ruggiero, 2010 | M | M | H | M | H | L | H | H | L | L | H | H
Ruggiero, 2014 | L | M | H | M | H | L | H | H | L | L | H | H
Sacco, 2009 | H | M | H | M | H | L | H | H | L | L | H | H
Salinero-Fort, 2011 | M | M | NA | M | NA | L | NA | L | L | L | NA | M
Samuel-Hodge, 2009 | L | M | H | M | H | L | H | M | M | L | H | M
Sarkadi, 2004 | L | L | H | M | H | L | M | M | L | L | H | M
Sevick, 2012 | L | M | NA | M | NA | L | NA | H | L | L | NA | H
Shibayama, 2007 | M | M | H | M | H | L | M | M | L | L | H | M
Sigurdardottir, 2009 | L | L | H | M | H | L | L | L | L | L | H | M
Siminerio, 2013 | M | M | M | M | M | L | M | M | L | L | M | M
Sinclair, 2013 | L | M | H | M | H | L | H | H | L | L | H | H
Sixta, 2008 | L | M | NA | M | NA | L | NA | H | L | L | NA | H
Skelly, 2005 | L | M | H | M | H | L | H | H | L | L | H | H
Skelly, 2009 | M | L | M | M | M | L | L | L | L | L | M | M
Smith, 1997 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Sorkin, 2014 | M | M | H | M | H | L | L | L | L | M | H | M
Spencer, 2011 | M | M | H | M | H | L | H | H | L | L | H | H
Sperl-Hillen, 2013 | L | M | H | M | H | L | M | L | H | L | H | H
Steed, 2005 | H | H | H | M | H | L | M | M | L | L | H | H
Sung, 2012 | L | M | H | M | H | L | M | M | L | L | H | M
Tang, 2014 | M | L | NA | L | NA | L | NA | H | M | L | NA | H
Thoolen, 2007 | L | M | H | M | H | L | H | H | L | L | H | H
Toobert, 2003 | M | M | H | M | H | L | H | H | L | L | H | H
Toobert, 2011 | M | M | H | M | H | L | H | H | L | L | H | H
Trief, 2011 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Tucker, 2014 | M | M | H | M | H | L | H | H | L | M | H | H
Utz, 2008 | L | M | M | M | M | L | M | M | L | L | M | M
Vadstrup, 2011 | L | M | M | M | M | L | M | M | L | L | M | M
Varney, 2014 | L | M | H | M | H | L | H | H | L | M | H | H
Vazquez, 1998 | M | M | H | M | H | L | M | M | L | L | H | M
Vincent, 2007 | L | M | H | M | H | L | H | H | L | L | H | H
Walker, 2011 | L | M | M | M | M | L | M | M | L | L | M | M
Weinger, 2011 | L | M | M | M | M | L | M | M | L | M | M | M
Welch, 2011 | M | M | NA | M | NA | L | NA | H | L | L | NA | H
Welschen, 2013 | L | L | H | M | H | L | L | L | L | H | H | H
West, 2007 | M | M | NA | M | NA | L | NA | L | L | L | NA | M
Wierenga, 1994 | M | M | H | M | H | L | H | H | M | L | H | H
Wing, 2013 | M | M | H | M | H | L | L | L | L | L | H | M
Wolever, 2010 | M | M | H | M | H | L | H | H | L | L | H | H
Wolf, 2004 | L | L | H | M | H | L | M | M | L | L | H | M
Yoo, 2007 | L | M | NA | M | NA | L | NA | H | L | L | NA | H
Yuan, 2014 | M | M | NA | M | NA | L | NA | H | L | M | NA | H
Zgibor, 2013 | M | M | M | M | M | L | H | H | L | L | H | H

* These trials may have reported on subjective (i.e., patient reported) outcomes but they were either not of interest to the review or not included in the analysis because of lacking data.

AC = allocation concealment; Blinding of OA = blinding of outcome assessors; Blinding of PP = blinding of participants and personnel; H = high risk of bias; IOD = incomplete outcome data; L = low risk of bias; M = medium or unclear risk of bias; NA = not applicable; Other = other sources of bias; Overall = overall risk of bias assessment; SG = sequence generation; SOR = selective outcome reporting