# Appendix D Studies Excluded After Full-Text Review

1 Aas AM, Bergstad I, Thorsby PM, et al. (2005). An intensified lifestyle intervention programme may be superior to insulin treatment in poorly controlled type 2 diabetic patients on oral hypoglycaemic agents: results of a feasibility study. Diabet Med.
2 Abolfotouh MA, Kamal MM, El-Bourgy MD, et al. (2011). Quality of life and glycemic control in adolescents with type 1 diabetes and the impact of an education intervention. Int J Gen Med.
3 Adams KF, Sperl-Hillen JaM, Davis H, et al. (2013). Factors influencing patient completion of diabetes self-management education. Diabetes Spectrum.
4 Adepoju OE, Bolin JN, Ohsfeldt RL, et al. (2014). Can chronic disease management programs for patients with type 2 diabetes reduce productivity-related indirect costs of the disease? Evidence from a randomized controlled trial. Popul Health Manag.
5 Adepoju OE, Bolin JN, Phillips CD, et al. (2014). Effects of diabetes self-management programs on time-to-hospitalization among patients with type 2 diabetes: a survival analysis model. Patient Educ Couns.
6 Adkins JW, Storch EA, Lewin AB, et al. (2006). Home-based behavioral health intervention: use of a telehealth model to address poor adherence to type-1 diabetes medical regimens. Telemed J E Health.
7 Agema P, Sherifali D. (2012). Determining the impact of an intervention to increase problem-solving skills in diabetes self-management: the diabetes problem-solving passport pilot study. Can.
8 Aikens JE, Rosland AM, Piette JD. (2014). Improvements in illness self-management and psychological distress associated with telemonitoring support for adults with diabetes. Prim Care Diabetes.
9 Al Mazroui NR, Kamal MM, Ghabash NM, et al. (2009). Influence of pharmaceutical care on health outcomes in patients with type 2 diabetes mellitus. Br J Clin Pharmacol.
10 Ali M, Schifano F, Robinson P, et al. (2012). Impact of community pharmacy diabetes monitoring and education programme on diabetes management: a randomized controlled study. Diabet Med.
11 Al-Jiffri O, Al-Sharif FM, Abd El-Kader SM, et al. (2013). Weight reduction improves markers of hepatic function and insulin resistance in type-2 diabetic patients with non-alcoholic fatty liver. Afr Health Sci.
12 Allen N, Whittemore R, Melkus G. (2011). A continuous glucose monitoring and problem-solving intervention to change physical activity behavior in women with type 2 diabetes: a pilot study. Diabetes Technol Ther.
13 Allen NA, Fain JA, Braun B, et al. (2008). Continuous glucose monitoring counseling improves physical activity behaviors of individuals with type 2 diabetes: a randomized clinical trial. Diabetes Res Clin Pract.
14 Ambrosino JM, Fennie K, Whittemore R, et al. (2008). Short-term effects of coping skills training in school-age children with type 1 diabetes. Pediatr Diabetes.
15 Amoako E, Skelly AH. (2007). Managing uncertainty in diabetes: an intervention for older African American women. Ethn Dis.
16 Anderson BJ, Brackett J, Ho J, et al. (2000). An intervention to promote family teamwork in diabetes management tasks: relationships among parental involvement, adherence to blood glucose monitoring, and glycemic control in young adolescents with type 1 diabetes. Drotar Dennis, editor.
17 (2001). ‘Behavior change’ is centerpiece of new disease management approach for diabetics. Dis Manag Advis.
18 (2005). Culturally appropriate lifestyle interventions promote weight loss in rural dwelling people with type 2 diabetes. Evidence-Based Healthcare and Public Health.
19 Ardigo D, Vaccaro O, Cavalot F, et al. (2014). Effectiveness of treat-to-target strategy for ldl-cholesterol control in type 2 diabetes: post-hoc analysis of data from the mind.it study. Eur J Prev Cardiolog.
20 Armstrong MJ, Campbell TS, Lewin AM, et al. (2013). Motivational interviewing-based exercise counselling promotes maintenance of physical activity in people with type 2 diabetes. Can.
21 Arseneau DL, Mason AC, Wood OB, et al. (1994). A comparison of learning activity packages and classroom instruction for diet management of patients with non-insulin-dependent diabetes mellitus. Diabetes Educ.
22 Ash S, Reeves MM, Yeo S, et al. (2003). Effect of intensive dietetic interventions on weight and glycaemic control in overweight men with type ii diabetes: a randomised trial. Int J Obes Relat Metab Disord.
23 Audet CM. (2014). A comparison of quality of life in traditional face-to-face and internet-based diabetes social support group participants. Dissertation Abstracts International: Section B: The Sciences and Engineering.
24 Avdal E, Kizilci S, Demirel N. (2011). The effects of web-based diabetes education on diabetes care results: a randomized control study. Comput Inform Nurs.
25 Bacchi E, Negri C, Trombetta M, et al. (2014). Differences in the acute effects of aerobic and resistance exercise in subjects with type 2 diabetes: results from the RAED2 randomized trial. Diabetes Technol Ther.
26 Balamurugan A, Hall-Barrow J, Blevins MA, et al. (2009). A pilot study of diabetes education via telemedicine in a rural underserved community-opportunities and challenges: a continuous quality improvement process. Diabetes Educ.
27 Balducci S, Zanuso S, Nicolucci A, et al. (2010). Effect of an intensive exercise intervention strategy on modifiable cardiovascular risk factors in subjects with type 2 diabetes mellitus: a randomized controlled trial: the Italian Diabetes and Exercise Study (IDES). Arch Intern Med.
28 Baradaran HR, Knill-Jones RP, Wallia S, et al. (2006). A controlled trial of the effectiveness of a diabetes education programme in a multi-ethnic community in Glasgow. BMC Public Health.
29 Barrera M, Strycker LA, Mackinnon DP, et al. (2008). Social-ecological resources as mediators of two-year diet and physical activity outcomes in type 2 diabetes patients. Health Psychol.
30 Barrera M, Toobert DJ, Angell KL, et al. (2006). Social support and social-ecological resources as mediators of lifestyle intervention effects for type 2 diabetes. J Health Psychol.
31 Barrera MJ, Glasgow RE, Mckay HG, et al. (2002). Do internet-based support interventions change perceptions of social support? an experimental trial of approaches for supporting diabetes self-management. Am J Community Psychol.
32 Basch CE, Walker EA, Howard CJ, et al. (1999). The effect of health education on the rate of ophthalmic examinations among African Americans with diabetes mellitus. Am J Public Health.
33 Bastelaar K, Cuijpers P, Pouwer F, et al. (2011). Development and reach of a web-based cognitive behavioural therapy programme to reduce symptoms of depression and diabetes-specific distress. Patient Educ Couns.
34 Batik O, Phelan EA, Walwick JA, et al. (2008). Translating a community-based motivational support program to increase physical activity among older adults with diabetes at community clinics: a pilot study of Physical Activity for a Lifetime of Success (PALS). Prev Chronic Dis.
35 Bellary S, O'hare JP, Raymond NT, et al. (2008). Enhanced diabetes care to patients of south Asian ethnic origin (the United Kingdom Asian diabetes study): a cluster randomised controlled trial. Lancet.
36 Berger G, Brunmayr F, Muehlehner M, et al. (2013). Gender differences in the effect of motivational interviewing and cognitive behavioural therapy in Austrian adolescents with type 1 diabetes. Diabetologia.
37 Berger M, Imershein SG, Jackson RA. (2013). Wait-list control study of a diabetes (dm) education program. Diabetes.
38 Beverly EA, Fitzgerald S, Sitnikov L, et al. (2013). Do older adults aged 60-75 years benefit from diabetes behavioral interventions?. Diabetes Care.
39 Blackberry ID, Furler JS, Best JD, et al. (2013). Effectiveness of general practice based, practice nurse led telephone coaching on glycaemic control of type 2 diabetes: the patient engagement and coaching for health (PEACH) pragmatic cluster randomised controlled trial. BMJ (Online).
40 Boehm S, Schlenk EA, Raleigh E, et al. (1993). Behavioral analysis and behavioral strategies to improve self-management of type ii diabetes. Clin Nurs Res.
41 Bradshaw BG. (2006). The efficacy of a resiliency training program in adults with type 2 diabetes mellitus.
42 Braun AK, Kubiak T, Kuntsche J, et al. (2009). SGS: a structured treatment and teaching programme for older patients with diabetes mellitus--a prospective randomised controlled multi-centre trial. Age Ageing.
43 Brazeau A-S, Gingras V, Leroux C, et al. (2014). A pilot program for physical exercise promotion in adults with type 1 diabetes: the PEP-1 program. Appl Physiol Nutr Metab.
44 Brown SA, Harrist RB, Villagomez ET, et al. (2000). Gender and treatment differences in knowledge, health beliefs, and metabolic control in Mexican Americans with type 2 diabetes. Diabetes Educ.
45 Byrne M, Newell J, Coffey N, et al. (2012). Predictors of quality of life gains among people with type 1 diabetes participating in the dose adjustment for normal eating (DAFNE) structured education programme. Diabetes Res Clin Pract.
46 Cabrera-Pivaral CE, Gonzalez-Perez G, Vega-Lopez G, et al. (2000). Effects of behavior-modifying education in the metabolic profile of the type 2 diabetes mellitus patient. J Diabetes Complications.
47 Cade JE, Kirk SF, Nelson P, et al. (2009). Can peer educators influence healthy eating in people with diabetes? results of a randomized controlled trial. Diabet Med.
48 Cakan N, Ellis DA, Templin T, et al. (2007). The effects of weight status on treatment outcomes in a randomized clinical trial of multisystemic therapy for adolescents with type 1 diabetes and chronically poor metabolic control. Pediatr Diabetes.
49 Calderon JL, Shaheen M, Hays RD, et al. (2014). Improving diabetes health literacy by animation. Diabetes Educ.
50 Campbell EM, Redman S, Moffitt PS, et al. (1996). The relative effectiveness of educational and behavioral instruction programs for patients with NIDDM: a randomized trial. Diabetes Educ.
51 Carter EL, Nunlee-Bland G, Callender C. (2011). A patient-centric, provider-assisted diabetes telehealth self-management intervention for urban minorities. Perspect.
52 Castaneda C, Layne JE, Munoz-Orians L, et al. (2002). A randomized controlled trial of resistance exercise training to improve glycemic control in older adults with type 2 diabetes. Diabetes Care.
53 Castillo A, Giachello A, Bates R, et al. (2010). Community-based diabetes education for Latinos: the diabetes empowerment education program. Diabetes Educ.
54 Cavanaugh K, Wallston KA, Gebretsadik T, et al. (2009). Addressing literacy and numeracy to improve diabetes care: two randomized controlled trials. Diabetes Care.
55 Chaney D, Coates V, Shevlin M. (2010). Running a complex educational intervention for adolescents with type 1 diabetes-lessons learnt. J Diabetes Nurs.
56 Channon SJ, Huws-Thomas MV, Rollnick S, et al. (2007). A multicenter randomized controlled trial of motivational interviewing in teenagers with diabetes. Diabetes Care.
57 Chao J, Yang L, Xu H, et al. (2015). The effect of integrated health management model on the health of older adults with diabetes in a randomized controlled trial. Arch Gerontol Geriatr.
58 Chesla CA, Kwan CML, Chun KM, et al. (2014). Gender differences in factors related to diabetes management in Chinese American immigrants. West J Nurs Res.
59 Cheyette C. (2007). Weight no more: a randomised controlled trial for people with type 2 diabetes on insulin therapy. Practical Diabetes International.
60 Chiu CJ, Lu FH, Hu YH, et al. (2014). Can telephone-based minimal psychological intervention be an effective method for diabetes self-management?. Diabetes.
61 Choe HM, Mitrovich S, Dubay D, et al. (2005). Proactive case management of high-risk patients with type 2 diabetes mellitus by a clinical pharmacist: a randomized controlled trial. Am J Manag Care.
62 Christian JG, Bessesen DH, Byers TE, et al. (2008). Clinic-based support to help overweight patients with type 2 diabetes increase physical activity and lose weight. Arch Intern Med.
63 Cinar AB, Schou L. (2014). The role of self-efficacy in health coaching and health education for patients with type 2 diabetes. Int Dent J.
64 Cinar AB, Schou L. (2014). The role of self-efficacy in health coaching and health education for patients with type 2 diabetes. Int Dent J.
65 Clancy DE, Huang P, Okonofua E, et al. (2007). Group visits: promoting adherence to diabetes guidelines. J Gen Intern Med.
66 Clifford RM, Batty KT, Davis TME, et al. (2002). A randomised controlled trial of a pharmaceutical care programme in high-risk diabetic patients in an outpatient clinic. Int J Pharm Pract.
67 Clobes TA. (2013). Patient compliance with type 2 diabetes using visual reminders and the transtheoretical model. Dissertation Abstracts International: Section B: The Sciences and Engineering.
68 Cohn MA, Pietrucha ME, Saslow LR, et al. (2014). An online positive affect skills intervention reduces depression in adults with type 2 diabetes. J Posit Psychol.
69 Conget I, Jansa M, Vidal M, et al. (1995). Effects of an individual intensive educational control program for insulin-dependent diabetic subjects with poor metabolic control. Diabetes Res Clin Pract.
70 Couper JJ, Taylor J, Fotheringham MJ, et al. (1999). Failure to maintain the benefits of home-based intervention in adolescents with poorly controlled type 1 diabetes. Diabetes Care.
71 Crasto W, Jarvis J, Khunti K, et al. (2011). Multifactorial intervention in individuals with type 2 diabetes and microalbuminuria: the Microalbuminuria Education and Medication Optimisation (MEMO) study. Diabetes Res Clin Pract.
72 Cummings DM, Lutes L, Littlewood K, et al. (2014). A small changes approach for lifestyle change is effective in non-insulin using African American women with uncontrolled type 2 diabetes: 12-month results from the empower trial. Diabetes.
73 Dale J, Caramlau I, Sturt J, et al. (2009). Telephone peer-delivered intervention for diabetes motivation and support: the telecare exploratory rct. Patient Educ Couns.
74 Daly KD. (2012). Test of a culturally sensitive health empowerment intervention on stress, health promoting behaviors, blood glucose and blood pressure among diverse adults with type 2 diabetes from low-income households. Dissertation Abstracts International: Section B: The Sciences and Engineering.
75 Daniels EC, Powe BD, Metoyer T, et al. (2012). Increasing knowledge of cardiovascular risk factors among African Americans by use of community health workers: the abcd community intervention pilot project. J Natl Med Assoc.
76 Davidson MB, Castellanos M, Kain D, et al. (2005). The effect of self monitoring of blood glucose concentrations on glycated hemoglobin levels in diabetic patients not taking insulin: a blinded, randomized trial. Am J Med.
77 Davies MJ, Heller S, Skinner TC, et al. (2008). Effectiveness of the diabetes education and self management for ongoing and newly diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ.
78 De Greef K, Deforche B, Tudor-Locke C, et al. (2011). Increasing physical activity in Belgian type 2 diabetes patients: a three-arm randomized controlled trial. Int J Behav Med.
79 De Greef KP, Deforche BI, Ruige JB, et al. (2011). The effects of a pedometer-based behavioral modification program with telephone support on physical activity and sedentary behavior in type 2 diabetes patients. Patient Educ Couns.
80 Deakin TA, Cade JE, Williams DRR, et al. (2003). Empowered patients: better diabetes control, greater freedom to eat, no weight gain!. Diabetologia.
81 Debussche X, Rollot O, Le Pommelet C, et al. (2012). Quarterly individual outpatients lifestyle counseling after initial inpatients education on type 2 diabetes: the redia prev-2 randomized controlled trial in reunion island. Diabetes Metab.
82 Decoster VA, George L. (2005). An empowerment approach for elders living with diabetes: a pilot study of a community-based self-help group-the diabetes club. Educ Gerontol.
83 Denig P, Schuling J, Haaijer-Ruskamp FM, et al. (2014). Effects of a patient-oriented decision aid for prioritising treatment goals in diabetes: a randomised controlled trial. Diabetologia.
84 Di Loreto C, Fanelli C, Lucidi P, et al. (2003). Validation of a counseling strategy to promote the adoption and the maintenance of physical activity by type 2 diabetic subjects. Diabetes Care.
85 Didjurgeit U, Kruse J, Schmitz N, et al. (2002). A time-limited, problem-orientated psychotherapeutic intervention in type 1 diabetic patients with complications: a randomized controlled trial. Diabet Med.
86 Diedrich A, Munroe DJ, Romano M. (2010). Promoting physical activity for persons with diabetes. Diabetes Educ.
87 Dijkstra RF, Braspenning JC, Huijsmans Z, et al. (2005). Introduction of diabetes passports involving both patients and professionals to improve hospital outpatient diabetes care. Diabetes Res Clin Pract.
88 Dijkstra RF, Niessen LW, Braspenning JCC, et al. (2006). Patient-centred and professional-directed implementation strategies for diabetes guidelines: a cluster-randomized trial-based cost-effectiveness analysis. Diabet Med.
89 Dinneen SF, O'hara MC, Byrne M, et al. (2013). Group follow-up compared to individual clinic visits after structured education for type 1 diabetes: a cluster randomised controlled trial. Diabetes Res Clin Pract.
90 Doucette WR, Witry MJ, Farris KB, et al. (2009). Community pharmacist-provided extended diabetes care. Ann Pharmacother.
91 Dunbar SB, Butts B, Reilly CM, et al. (2014). A pilot test of an integrated self-care intervention for persons with heart failure and concomitant diabetes. Nurs Outlook.
92 Dunbar SB, Reilly CM, Gary RA, et al. (2014). An integrated self care education and counseling intervention for persons with heart failure and diabetes improves quality of life and physical functioning. J Card Fail.
93 Dunstan DW, Mori TA, Puddey IB, et al. (1998). Exercise and fish intake: effects on serum lipids and glycemic control for type 2 diabetics. Cardiology Review.
94 Dunstan DW, Mori TA, Puddey IB, et al. (1999). A randomised, controlled study of the effects of aerobic exercise and dietary fish on coagulation and fibrinolytic factors in type 2 diabetics. Thromb Haemost.
95 Dunstan DW, Puddey IB, Beilin LJ, et al. (1998). Effects of a short-term circuit weight training program on glycaemic control in NIDDM. Diabetes Res Clin Pract.
96 Duran A, Martin P, Runkle I, et al. (2010). Benefits of self-monitoring blood glucose in the management of new-onset type 2 diabetes mellitus: the St Carlos study, a prospective randomized clinic-based interventional study with parallel groups. J Diabetes.
97 Dutton GR, Provost BC, Tan F, et al. (2008). A tailored print-based physical activity intervention for patients with type 2 diabetes. Prev Med.
98 Eakin E, Reeves M, Dunstan D, et al. (2012). Living well with diabetes: six-month randomised trial outcomes of a telephone-delivered weight loss intervention. J Sci Med Sport.
99 Eakin E, Reeves M, Lawler S, et al. (2009). Telephone counseling for physical activity and diet in primary care patients. Am J Prev Med.
100 Eakin E, Reeves M, Winkler E, et al. (2010). Maintenance of physical activity and dietary change following a telephone-delivered intervention. Health Psychol.
101 Eakin EG, Reeves MM, Lawler SP, et al. (2008). The logan healthy living program: a cluster randomized trial of a telephone-delivered physical activity and dietary behavior intervention for primary care patients with type 2 diabetes or hypertension from a socially disadvantaged community--rationale, design and recruitment. Contemp Clin Trials.
102 Eakin EG, Reeves MM, Winkler E, et al. (2013). Six-month outcomes from living well with diabetes: a randomized trial of a telephone-delivered weight loss and physical activity intervention to improve glycemic control. Ann Behav Med.
103 Edelman D, Fredrickson SK, Melnyk SD, et al. (2010). Medical clinics versus usual care for patients with both diabetes and hypertension: a randomized trial. Ann Intern Med.
104 Elnour AA, El Mugammar IT, Jaber T, et al. (2008). Pharmaceutical care of patients with gestational diabetes mellitus. J Eval Clin Pract.
105 Engel L, Cummins R. (2011). Impact of dose adjustment for normal eating in Australia (ozdafne) on subjective wellbeing, coping resources and negative affects in adults with type 1 diabetes: a prospective comparison study. Diabetes Res Clin Pract.
106 Engel L, Lindner H. (2006). Impact of using a pedometer on time spent walking in older adults with type 2 diabetes. Diabetes Educ.
107 Eriksson KM, Westborg CJ, Eliasson MCE. (2006). A randomized trial of lifestyle intervention in primary healthcare for the modification of cardiovascular risk factors: the BJORKNAS study. Scand J Public Health.
108 Esmatjes E, Jansà M, Roca D, et al. (2014). The efficiency of telemedicine to optimize metabolic control in patients with type 1 diabetes mellitus: telemed study. Diabetes Technol Ther.
109 Espeland MA, Glick HA, Bertoni A, et al. (2014). Impact of an intensive lifestyle intervention on use and cost of medical services among overweight and obese adults with type 2 diabetes: the action for health in diabetes. Diabetes Care.
110 Espeland MA, Rapp SR, Bray GA, et al. (2014). Long-term impact of behavioral weight loss intervention on cognitive function. J Gerontol A Biol Sci Med Sci.
111 Espeland MA, Rejeski WJ, West DS, et al. (2013). Intensive weight loss intervention in older individuals: results from the action for health in diabetes type 2 diabetes mellitus trial. J Am Geriatr Soc.
112 Esposito K, Maiorino MI, Petrizzo M, et al. (2014). The effects of a Mediterranean diet on the need for diabetes drugs and remission of newly diagnosed type 2 diabetes: follow-up of a randomized trial. Diabetes Care.
113 Estabrooks PA, Nelson CC, Xu S, et al. (2005). The frequency and behavioral outcomes of goal choices in the self-management of diabetes. Diabetes Educ.
114 Fabricatore AN, Wadden TA, Ebbeling CB, et al. (2011). Targeting dietary fat or glycemic load in the treatment of obesity and type 2 diabetes: a randomized controlled trial. Diabetes Res Clin Pract.
115 Faridi Z, Liberti L, Shuval K, et al. (2008). Evaluating the impact of mobile telephone technology on type 2 diabetic patients' self-management: the niche pilot study. J Eval Clin Pract.
116 Farmer A, Wade A, Goyder E, et al. (2007). Impact of self monitoring of blood glucose in the management of patients with non-insulin treated diabetes: open parallel group randomised trial. BMJ.
117 Farmer AJ, Wade AN, French DP, et al. (2009). Blood glucose self-monitoring in type 2 diabetes: a randomised controlled trial. Health Technol Assess.
118 Faulconbridge LF, Wadden TA, Rubin RR, et al. (2012). One-year changes in symptoms of depression and weight in overweight/obese individuals with type 2 diabetes in the Look Ahead study. Obesity (Silver Spring).
119 Fitzpatrick SL, Jeffery R, Johnson KC, et al. (2014). Baseline predictors of missed visits in the Look Ahead study. Obesity (Silver Spring).
120 Forjuoh SN, Bolin JN, Huber JCJ, et al. (2014). Behavioral and technological interventions targeting glycemic control in a racially/ethnically diverse population: a randomized controlled trial. BMC Public Health.
121 Forjuoh SN, Ory MG, Jiang L, et al. (2014). Impact of chronic disease self-management programs on type 2 diabetes management in primary care. World J Diabetes.
122 Fornos JA, Andres NF, Andres JC, et al. (2006). A pharmacotherapy follow-up program in patients with type-2 diabetes in community pharmacies in Spain. Pharm World Sci.
123 Foster GD, Borradaile KE, Sanders MH, et al. (2009). A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the sleep ahead study. Arch Intern Med.
124 Foster GD, Wyatt HR, Hill JO, et al. (2010). Weight and metabolic outcomes after 2 years on a low-carbohydrate versus low-fat diet: a randomized trial. Ann Intern Med.
125 Franciosi M, Lucisano G, Pellegrini F, et al. (2011). Roses: role of self-monitoring of blood glucose and intensive education in patients with type 2 diabetes not receiving insulin. A pilot randomized clinical trial. Diabet Med.
126 Freeman KA, Duke DC, Harris MA. (2014). Behavioral health care for adolescents with poorly controlled diabetes via skype: does working alliance remain intact?. J Diabetes Sci Technol.
127 Gabbay RA, Lendel I, Saleem TM, et al. (2006). Nurse case management improves blood pressure, emotional distress and diabetes complication screening. Diabetes Res Clin Pract.
128 Gaede P, Beck M, Vedel P, et al. (2001). Limited impact of lifestyle education in patients with type 2 diabetes mellitus and microalbuminuria: results from a randomized intervention study. Diabet Med.
129 Gaede P, Lund-Andersen H, Parving HH, et al. (2008). Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med.
130 Gaede P, Vedel P, Larsen N, et al. (2003). Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med.
131 Gaede P, Vedel P, Parving HH, et al. (1999). Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the steno type 2 randomised study. Lancet.
132 Gajewska KA, Pankowska E, Gajewski JA. (2012). The to become independent - educational program for young adolescents. The pilot study of original program. Pediatr Diabetes.
133 Gallagher R, Kirkness A, Zelestis E, et al. (2012). A randomised trial of a weight loss intervention for overweight and obese people diagnosed with coronary heart disease and/or type 2 diabetes. Ann Behav Med.
134 Gallagher R, Zelestis E, Hollams D, et al. (2014). Impact of the healthy eating and exercise lifestyle programme on depressive symptoms in overweight people with heart disease and diabetes. Eur J Prev Cardiolog.
135 Ganz DA. (2008). Measuring the quality of chronic illness care for older adults. Dissertation Abstracts International: Section B: The Sciences and Engineering.
136 Garcia-Lopez M, Toledo E, Beunza JJ, et al. (2014). Mediterranean diet and heart rate: the predimed randomised trial. Int J Cardiol.
137 Gary TL, Batts-Turner M, Yeh HC, et al. (2009). The effects of a nurse case manager and a community health worker team on diabetic control, emergency department visits, and hospitalizations among urban African Americans with type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med.
138 Gary TL, Bone LR, Hill MN, et al. (2003). Randomized controlled trial of the effects of nurse case manager and community health worker interventions on risk factors for diabetes-related complications in urban African Americans. Prev Med.
139 Gibbs BB, Brancati FL, Chen H, et al. (2014). Effect of improved fitness beyond weight loss on cardiovascular risk factors in individuals with type 2 diabetes in the Look Ahead study. Eur J Prev Cardiolog.
140 Gillespie P, Oshea E, O'hara MC, et al. (2014). Cost effectiveness of group follow-up after structured education for type 1 diabetes: a cluster randomised controlled trial. Trials.
141 Gillespie P, O'shea E, Paul G, et al. (2012). Cost effectiveness of peer support for type 2 diabetes. Int J Technol Assess Health Care.
142 Glasgow RE, Boles SM, Mckay HG, et al. (2003). The d-net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med.
143 Glasgow RE, Christiansen SM, Kurz D, et al. (2011). Engagement in a diabetes self-management website: usage patterns and generalizability of program use. J Med Internet Res.
144 Glasgow RE, Edwards LL, Whitesides H, et al. (2009). Reach and effectiveness of dvd and in-person diabetes self-management education. Chronic Illn.
145 Glasgow RE, La Chance PA, Toobert DJ, et al. (1997). Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Patient Educ Couns.
146 Glasgow RE, Strycker LA, King DK, et al. (2014). Understanding who benefits at each step in an internet-based diabetes self-management program: application of a recursive partitioning approach. Med Decis Making.
147 Glasgow RE, Toobert DJ. (2000). Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care.
148 Glasgow RE, Toobert DJ, Barrera MJ, et al. (2004). Assessment of problem-solving: a key to successful diabetes self-management. J Behav Med.
149 Glasgow RE, Toobert DJ, Hampson SE. (1996). Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care.
150 Glasgow RE, Toobert DJ, Hampson SE, et al. (1995). A brief office-based intervention to facilitate diabetes dietary self-management. Health Educ Res.
151 Glasgow RE, Toobert DJ, Hampson SE, et al. (2002). Implementation, generalization and long-term results of the “choosing well” diabetes self-management intervention. Patient Educ Couns.
152 Goode AD, Winkler EA, Reeves MM, et al. (2014). Relationship between intervention dose and outcomes in living well with diabetes-a randomized trial of a telephone-delivered lifestyle-based weight loss intervention. Am J Health Promot.
153 Goode AD, Winkler EaH, Lawler SP, et al. (2011). A telephone-delivered physical activity and dietary intervention for type 2 diabetes and hypertension: does intervention dose influence outcomes?. Am J Health Promot.
154 Graue M, Wentzel-Larsen T, Hanestad BR, et al. (2005). Evaluation of a programme of group visits and computer-assisted consultations in the treatment of adolescents with type 1 diabetes. Diabet Med.
155 Greenhalgh T, Campbell-Richards D, Vijayaraghavan S, et al. (2011). New models of self-management education for minority ethnic groups: pilot randomized trial of a story-sharing intervention. J Health Serv Res Policy.
156 Greenwood DA, Kramer MK, Hankins AI, et al. (2014). Adapting the group lifestyle balance™ program for weight management within a large health care system diabetes education program. Diabetes Educ.
157 Gregg JA, Callaghan GM, Hayes SC, et al. (2007). Improving diabetes self-management through acceptance, mindfulness, and values: a randomized controlled trial. J Consult Clin Psychol.
158 Grey M, Boland EA, Davidson M, et al. (2000). Coping skills training for youth with diabetes mellitus has long-lasting effects on metabolic control and quality of life. J Pediatr.
159 Grey M, Boland EA, Davidson M, et al. (1998). Short-term effects of coping skills training as adjunct to intensive therapy in adolescents. Diabetes Care.
160 Grey M, Boland EA, Davidson M, et al. (1999). Coping skills training for youths with diabetes on intensive therapy. Appl Nurs Res.
161 Grey M, Davidson M, Boland EA, et al. (2001). Clinical and psychosocial factors associated with achievement of treatment goals in adolescents with diabetes mellitus. J Adolesc Health.
162 Grey M, Whittemore R, Jaser S, et al. (2009). Effects of coping skills training in school-age children with type 1 diabetes. Res Nurs Health.
163 Grey M, Whittemore R, Jeon S, et al. (2013). Internet psycho-education programs improve outcomes in youth with type 1 diabetes. Diabetes Care.
164 Group CM-CS. (2004). Closing the gap: effect of diabetes case management on glycemic control among low-income ethnic minority populations: the California medi-cal type 2 diabetes study. Diabetes Care.
165 Group DS. (2002). Training in flexible, intensive insulin management to enable dietary freedom in people with type 1 diabetes: dose adjustment for normal eating (DAFNE) randomised controlled trial. BMJ.
166 Gucciardi E, Demelo M, Lee RN, et al. (2007). Assessment of two culturally competent diabetes education methods: individual versus individual plus group education in Canadian Portuguese adults with type 2 diabetes. Ethn Health.
167 Guerci B, Drouin P, Grange V, et al. (2003). Self-monitoring of blood glucose significantly improves metabolic control in patients with type 2 diabetes mellitus: the auto-surveillance intervention active (ASIA) study. Diabetes Metab.
168 Guldbrand H, Lindstrom T, Dizdar B, et al. (2014). Randomization to a low-carbohydrate diet advice improves health related quality of life compared with a low-fat diet at similar weight-loss in type 2 diabetes mellitus. Diabetes Res Clin Pract.
169 Ha M, Hu J, Petrini MA, et al. (2014). The effects of an educational self-efficacy intervention on osteoporosis prevention and diabetes self-management among adults with type 2 diabetes mellitus. Biol Res Nurs.
170 Hains AA, Davies WH, Parton E, et al. (2000). A stress management intervention for adolescents with type 1 diabetes. Diabetes Educ.
171 Halbron M, Sachon C, Simon D, et al. (2014). Evaluation of a 5-day education programme in type 1 diabetes: achieving individual targets with a patient-centred approach. Diabet Med.
172 Halford WK, Goodall TA, Nicholson JM. (1997). Diet and diabetes (ii): a controlled trial of problem solving to improve dietary self-management in patients with insulin dependent diabetes. Psychol Health.
173 Halle M, Berg A, Garwers U, et al. (1999). Influence of 4 weeks' intervention by exercise and diet on low-density lipoprotein subfractions in obese men with type 2 diabetes. Metabolism.
174 Hamdy O, Carver C. (2008). The why wait program: improving clinical outcomes through weight management in type 2 diabetes. Curr Diab Rep.
175 Hamid S, Dunsiger S, Seiden A, et al. (2014). Impact of a diabetes control and management intervention on health care utilization in American Samoa. Chronic Illn.
176 Hardeman W, Lamming L, Kellar I, et al. (2014). Implementation of a nurse-led behaviour change intervention to support medication taking in type 2 diabetes: beyond hypothesised active ingredients (sams consultation study). Implement Sci.
177 Hare JL, Hordern MD, Leano R, et al. (2011). Application of an exercise intervention on the evolution of diastolic dysfunction in patients with diabetes mellitus: efficacy and effectiveness. Circ.
178 Hargraves JL, Ferguson WJ, Lemay CA, et al. (2012). Community health workers assisting patients with diabetes in self-management. J Ambulatory Care Manage.
179 Harris MA, Freeman KA, Beers M. (2009). Family therapy for adolescents with poorly controlled diabetes: initial test of clinical significance. J Pediatr Psychol.
180 Harris MA, Freeman KA, Duke DC, et al. (2013). Skype-based family problem solving for youth with poorly controlled diabetes: relative effectiveness of improving adherence and metabolic control. Diabetes.
181 Harris MA, Greco P, Wysocki T, et al. (2001). Family therapy with adolescents with diabetes: a litmus test for clinically meaningful change. Fam Syst Health.
182 Hawthorne K. (2001). Effect of culturally appropriate health education on glycaemic control and knowledge of diabetes in British Pakistani women with type 2 diabetes mellitus. Health Educ Res.
183 Hawthorne K, Tomlinson S. (1997). One-to-one teaching with pictures--flashcard health education for British Asians with diabetes. Br J Gen Pract.
184 Headley S, Germain M, Wood R, et al. (2014). Short-term aerobic exercise and vascular function in ckd stage 3: a randomized controlled trial. Am J Kidney Dis.
185 Hee-Sung K. (2007). Impact of web-based nurse's education on glycosylated haemoglobin in type 2 diabetic patients. J Clin Nurs.
186 Heinrich E, Candel MJ, Schaper NC, et al. (2010). Effect evaluation of a motivational interviewing based counselling strategy in diabetes care. Diabetes Res Clin Pract.
187 Heinrich E, De Nooijer J, Schaper NC, et al. (2012). Evaluation of the web-based diabetes interactive education programme (DIEP) for patients with type 2 diabetes. Patient Educ Couns.
188 Heisler M, Vijan S, Makki F, et al. (2010). Diabetes control with reciprocal peer support versus nurse care management: a randomized trial. Ann Intern Med.
189 Hellgren MI, Petzold M, Beteus-Forslund H, et al. (2014). Feasibility of a randomized controlled intervention with physical activity in participants with impaired glucose tolerance recruited by FINDRISC: a pilot study. Scand J Public Health.
190 Henry JL, Wilson PH, Bruce DG, et al. (1997). Cognitive-behavioural stress management for patients with non-insulin dependent diabetes mellitus. Psychol Health Med.
191 Hermanns N, Kulzer B, Kubiak T, et al. (2007). The effect of an education programme (HYPOS) to treat hypoglycaemia problems in patients with type 1 diabetes. Diabetes Metab Res Rev.
192 Hiss RG, Armbruster BA, Gillard ML, et al. (2007). Nurse care manager collaboration with community-based physicians providing diabetes care: a randomized controlled trial. Diabetes Educ.
193 Hiss RG, Gillard ML, Armbruster BA, et al. (2001). Comprehensive evaluation of community-based diabetic patients: effect of feedback to patients and their physicians: a randomized controlled trial. Diabetes Care.
194 (2014). Daily text messages and nurse follow-up improve self-management in patients with diabetes. Home Healthc Nurse.
195 (2014). Innovative diabetes self-management programs identified for urban patients who speak various languages. Home Healthc Nurse.
196 Hood KK, Weissberg-Benchell J. (2014). Supporting teen problem solving (STEPS): depression prevention for teens with t1d. Diabetes.
197 Hornsten A, Lundman B, Stenlund H, et al. (2005). Metabolic improvement after intervention focusing on personal understanding in type 2 diabetes. Diabetes Res Clin Pract.
198 Hornsten A, Stenlund H, Lundman B, et al. (2008). Improvements in hba1c remain after 5 years-a follow up of an educational intervention focusing on patients' personal understandings of type 2 diabetes. Diabetes Res Clin Pract.
199 Houston DK, Leng X, Bray GA, et al. (2015). A long-term intensive lifestyle intervention and physical function: the Look Ahead movement and memory study. Obesity (Silver Spring).
200 Howe CJ, Jawad AF, Tuttle AK, et al. (2005). Education and telephone case management for children with type 1 diabetes: a randomized controlled trial. J Pediatr Nurs.
201 Howells L, Wilson AC, Skinner TC, et al. (2002). A randomized control trial of the effect of negotiated telephone support on glycaemic control in young people with type 1 diabetes. Diabet Med.
202 Howorka K, Pumprla J, Wagner-Nosiska D, et al. (2000). Empowering diabetes out-patients with structured education: short-term and long-term effects of functional insulin treatment on perceived control over diabetes. J Psychosom Res.
203 Huizinga MM, Gebretsadik T, Garcia Ulen C, et al. (2010). Preventing glycaemic relapse in recently controlled type 2 diabetes patients: a randomised controlled trial. Diabetologia.
204 Hunt CW, Sanderson BK, Ellison KJ. (2014). Support for diabetes using technology: a pilot study to improve self-management. Medsurg Nurs.
205 Iafusco D, Galderisi A, Nocerino I, et al. (2011). Chat line for adolescents with type 1 diabetes: a useful tool to improve coping with diabetes: a 2-year follow-up study. Diabetes Technol Ther.
206 Izquierdo R, Lagua CT, Meyer S, et al. (2010). Telemedicine intervention effects on waist circumference and body mass index in the ideatel project. Diabetes Technol Ther.
207 Jaber LA, Halapy H, Fernet M, et al. (1996). Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother.
208 Jaber LA, Halapy H, Fernet M, et al. (1996). Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother.
209 Jablon SL, Naliboff BD, Gilmore SL, et al. (1997). Effects of relaxation training on glucose tolerance and diabetic control in type ii diabetes. Appl Psychophysiol Biofeedback.
210 Jackson R, Asimakopoulou K, Scammell A. (2007). Assessment of the transtheoretical model as used by dietitians in promoting physical activity in people with type 2 diabetes. J Hum Nutr Diet.
211 Jahangard-Rafsanjani Z, Sarayani A, Nosrati M, et al. (2014). Effect of a community pharmacist-delivered diabetes support program for patients receiving specialty medical care: a randomized controlled trial. Diabetes Educ.
212 Jakicic JM, Egan CM, Fabricatore AN, et al. (2013). Four-year change in cardiorespiratory fitness and influence on glycemic control in adults with type 2 diabetes in a randomized trial: the Look Ahead trial. Diabetes Care.
213 Jakicic JM, Jaramillo SA, Balasubramanyam A, et al. (2009). Effect of a lifestyle intervention on change in cardiorespiratory fitness in adults with type 2 diabetes: results from the Look Ahead study. Int J Obes (Lond).
214 Jalilian M, Moeini B, Hazavehei SMM, et al. (2013). Physical activity stage-matched intervention: promoting metabolic control in type 2 diabetes. J Educ Health Promot.
215 Jansa M, Vidal M, Viaplana J, et al. (2006). Telecare in a structured therapeutic education programme addressed to patients with type 1 diabetes and poor metabolic control. Diabetes Res Clin Pract.
216 Jansink R, Braspenning J, Keizer E, et al. (2013). No identifiable hb1ac or lifestyle change after a comprehensive diabetes programme including motivational interviewing: a cluster randomised trial. Scand J Prim Health Care.
217 Jaser SS, Patel N, Rothman RL, et al. (2014). A randomized pilot of a positive psychology intervention to improve adherence in adolescents with type 1 diabetes. Diabetes Educ.
218 Jennings CA, Vandelanotte C, Caperchione CM, et al. (2014). Effectiveness of a web-based physical activity intervention for adults with type 2 diabetes-a randomised controlled trial. Prev Med.
219 Johannsen NM, Sparks LM, Zhang Z, et al. (2014). Determinants of the changes in glycemic control with exercise training in type 2 diabetes: a randomized trial. Diabetes Technol Ther.
220 Johansen OE, Gullestad L, Blaasaas KG, et al. (2007). Effects of structured hospital-based care compared with standard care for type 2 diabetes-the asker and baerum cardiovascular diabetes study, a randomized trial. Diabet Med.
221 Johnson W, Shaya FT, Winston R, et al. (2014). Diabetes control through an educational intervention. Ethn Dis.
222 Johnston CA, Moreno JP, Foreyt JP. (2014). Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. Curr Atheroscler Rep.
223 Joshi R, Joshi N, Helmuth A. (2010). Improving ambulatory diabetes care in high-risk racial minorities: use of culture-specific education and close follow-up. Endocr Pract.
224 Kahleova H, Matoulek M, Malinska H, et al. (2011). Vegetarian diet improves insulin resistance and oxidative stress markers more than conventional diet in subjects with type 2 diabetes. Diabet Med.
225 Kang CM, Chang SC, Chen PL, et al. (2010). Comparison of family partnership intervention care vs. conventional care in adult patients with poorly controlled type 2 diabetes in a community hospital: a randomized controlled trial. Int J Nurs Stud.
226 Karstoft K, Christensen CS, Pedersen BK, et al. (2014). The acute effects of interval vs continuous-walking exercise on glycemic control in subjects with type 2 diabetes: a crossover, controlled study. J Clin Endocrinol Metab.
227 Kempf K, Schloot NC, Gärtner B, et al. (2014). Meal replacement reduces insulin requirement, hba1c and weight long-term in type 2 diabetes patients with >100 u insulin per day. J Hum Nutr Diet.
228 Kenya S, Lebron C, Reyes Arrechea E, et al. (2014). Glucometer use and glycemic control among Hispanic patients with diabetes in Southern Florida. Clin Ther.
229 Kerr D, Gillam E, Ryder J, et al. (2002). An eastern art form for a western disease: randomised controlled trial of yoga in patients with poorly controlled insulin-treated diabetes. Practical Diabetes International.
230 Keyserling TC, Ammerman AS, Samuel-Hodge CD, et al. (2000). A diabetes management program for African American women with type 2 diabetes. Diabetes Educ.
231 Khosravizade TH, Madarshahian F, Khoshniat NM, et al. (2014). Impact of family support improvement behaviors on anti diabetic medication adherence and cognition in type 2 diabetic patients. J Diabetes Metab Disord.
232 Kim HJ, Kang CK, Park H, et al. (2014). Effects of vitamin d supplementation and circuit training on indices of obesity and insulin resistance in t2d and vitamin d deficient elderly women. J Exerc Nutrition Biochem.
233 Kim HS, Oh JA. (2003). Adherence to diabetes control recommendations: impact of nurse telephone calls. J Adv Nurs.
234 Kim HS, Oh JA, Lee HO. (2005). Effects of nurse-coordinated intervention on patients with type 2 diabetes in korea. J Nurs Care Qual.
235 Kim SI, Kim HS. (2008). Effectiveness of mobile and internet intervention in patients with obese type 2 diabetes. Int J Med Inform.
236 King DK, Glasgow RE, Toobert DJ, et al. (2010). Self-efficacy, problem solving, and social-environmental support are associated with diabetes self-management behaviors. Diabetes Care.
237 Kirk A, Mutrie N, Macintyre P, et al. (2003). Increasing physical activity in people with type 2 diabetes. Diabetes Care.
238 Kirk A, Mutrie N, Macintyre P, et al. (2004). Effects of a 12-month physical activity counselling intervention on glycaemic control and on the status of cardiovascular risk factors in people with type 2 diabetes. Diabetologia.
239 Kirkman MS, Weinberger M, Landsman PB, et al. (1994). A telephone-delivered intervention for patients with NIDDM: effect on coronary risk factors. Diabetes Care.
240 Ko GT, Li JK, Kan EC, et al. (2004). Effects of a structured health education programme by a diabetic education nurse on cardiovascular risk factors in Chinese type 2 diabetic patients: a 1-year prospective randomized study. Diabet Med.
241 Kolbasovsky A. (2005). A pilot project to address the behavioral health needs of people with diabetes. Manag Care Interface.
242 Kolbasovsky A, Reich L. (2010). Improving the quality of diabetes care: a behavioral health intervention. J Healthc Qual.
243 Koproski J, Pretto Z, Poretsky L. (1997). Effects of an intervention by a diabetes team in hospitalized patients with diabetes. Diabetes Care.
244 Korytkowski MT, Koerbel GL, Kotagal L, et al. (2014). Pilot trial of diabetes self-management education in the hospital setting. Prim Care Diabetes.
245 Kraemer DF, Kradjan WA, Bianco TM, et al. (2012). A randomized study to assess the impact of pharmacist counseling of employer-based health plan beneficiaries with diabetes: the empower study. J Pharm Pract.
246 Krakow D, Feulner-Krakow G. (2007). Linda. The diabetes self-management training programme for people with type 1 or type 2 diabetes. European Diabetes Nursing.
247 Krein SL, Klamerus ML, Vijan S, et al. (2004). Case management for patients with poorly controlled diabetes: a randomized trial. Am J Med.
248 Krein SL, Klamerus ML, Vijan S, et al. (2004). Case management for patients with poorly controlled diabetes: a randomized trial. Am J Med.
249 Kroese FM, Adriaanse MA, Vinkers CDW, et al. (2014). The effectiveness of a proactive coping intervention targeting self-management in diabetes patients. Psychol Health.
250 Krousel-Wood MA, Berger L, Jiang X, et al. (2008). Does home-based exercise improve body mass index in patients with type 2 diabetes? Results of a feasibility trial. Diabetes Res Clin Pract.
251 Kulzer B, Hermanns N, Ehrmann D, et al. (2013). The effect of a diabetes education programme (PRIMAS) for people with type 1 diabetes: results of a randomized trial. Diabetes.
252 Kuznetsov L, Long GH, Griffin SJ, et al. (2014). Are changes in glycaemic control associated with diabetes-specific quality of life and health status in screen-detected type 2 diabetes patients? Four-year follow up of the addition-cambridge cohort. Diabetes Metab Res Rev.
253 Lagger G, Golay A. (2010). A 5 dimension therapeutic patient education for type 1 diabetic patients. Education Therapeutique du Patient/Therapeutic Patient Education.
254 Laitinen J, Uusitupa M, Ahola I, et al. (1994). Metabolic and dietary variables associated with glycaemic control in patients with recently diagnosed type ii diabetes mellitus. Diabetes Nutr Metab.
255 Lane JD, Mccaskill CC, Ross SL, et al. (1993). Relaxation training for NIDDM. Predicting who may benefit. Diabetes Care.
256 Lawler SP, Winkler E, Reeves MM, et al. (2010). Multiple health behavior changes and co-variation in a telephone counseling trial. Ann Behav Med.
257 Lawson ML, Cohen N, Richardson C, et al. (2005). A randomized trial of regular standardized telephone contact by a diabetes nurse educator in adolescents with poor diabetes control. Pediatr Diabetes.
258 Legorreta AP, Peters AL, Ossorio RC, et al. (1996). Effect of a comprehensive nurse-managed diabetes program: an HMO prospective study. Am J Manag Care.
259 Levetan CS, Dawn KR, Robbins DC, et al. (2002). Impact of computer-generated personalized goals on hba(1c). Diabetes Care.
260 Li X, Zhang H, Yuan B, et al. (2008). Study on effect of pharmacist participating in medication guidance of diabetic patients at home. Journal of Clinical and Experimental Medicine.
261 Ligtenberg PC, Hoekstra JB, Bol E, et al. (1997). Effects of physical training on metabolic control in elderly type 2 diabetes mellitus patients. Clinical science (London, England : 1979).
262 Lipkin EW, Schwartz AV, Anderson AM, et al. (2014). The Look Ahead trial: bone loss at 4-year follow-up in type 2 diabetes. Diabetes Care.
263 Lo R, Lo B, Wells E, et al. (1996). The development and evaluation of a computer-aided diabetes education program. Aust J Adv Nurs.
264 Look ARG, Pi-Sunyer X, Blackburn G, et al. (2007). Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the Look Ahead trial. Diabetes Care.
265 Look ARG, Wing RR. (2010). Long-term effects of a lifestyle intervention on weight and cardiovascular risk factors in individuals with type 2 diabetes mellitus: four-year results of the Look Ahead trial. Arch Intern Med.
266 Lorig KR, Ritter PL, Gonzalez VM. (2003). Hispanic chronic disease self-management: a randomized community-based outcome trial. Nurs Res.
267 Lucotti P, Monti LD, Setola E, et al. (2011). Aerobic and resistance training effects compared to aerobic training alone in obese type 2 diabetic patients on diet treatment. Diabetes Res Clin Pract.
268 Lukács A, Varga B, Kiss-Tóth E, et al. (2014). Factors influencing the diabetes-specific health-related quality of life in children and adolescents with type 1 diabetes mellitus. J Child Health Care.
269 Luley C, Blaik A, Reschke K, et al. (2011). Weight loss in obese patients with type 2 diabetes: effects of telemonitoring plus a diet combination - the active body control (ABC) program. Diabetes Res Clin Pract.
270 Lynch EB, Liebman R, Ventrelle J, et al. (2014). Design of the lifestyle improvement through food and exercise (LIFE) study: a randomized controlled trial of self-management of type 2 diabetes among African American patients from safety net health centers. Contemp Clin Trials.
271 Macphail M, Mullan B, Sharpe L, et al. (2014). Using the health action process approach to predict and improve health outcomes in individuals with type 2 diabetes mellitus. Diabetes Metab Syndr Obes.
272 Magee MF, Khan NH, Desale S, et al. (2014). Diabetes to go: knowledge- and competency-based hospital survival skills diabetes education program improves postdischarge medication adherence. Diabetes Educ.
273 Maindal HT, Carlsen AH, Lauritzen T, et al. (2014). Effect of a participant-driven health education programme in primary care for people with hyperglycaemia detected by screening: 3-year results from the ready to act randomized controlled trial (nested within the addition-Denmark study). Diabet Med.
274 Maislos M, Weisman D. (2004). Multidisciplinary approach to patients with poorly controlled type 2 diabetes mellitus: a prospective, randomized study. Acta Diabetol.
275 Maljanian R, Grey N, Staff I, et al. (2005). Intensive telephone follow-up to a hospital-based disease management model for patients with diabetes mellitus. Dis Manag.
276 Maloni HW. (2007). An intervention to effect hypertension, glycemic control, diabetes self-management, self-efficacy, and satisfaction with care in type 2 diabetic va health care users with inadequate functional health literacy skills. Dissertation Abstracts International: Section B: The Sciences and Engineering.
277 Mandalia PK, Stone MA, Davies MJ, et al. (2014). Diabetes self-management education: acceptability of using trained lay educators. Postgrad Med J.
278 Manning RM, Jung RT, Leese GP, et al. (1995). The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabet Med.
279 Manning RM, Jung RT, Leese GP, et al. (1998). The comparison of four weight reduction strategies aimed at overweight patients with diabetes mellitus: four-year follow-up. Diabet Med.
280 Martinus R, Corban R, Wackerhage H, et al. (2006). Effect of psychological intervention on exercise adherence in type 2 diabetic subjects. Ann N Y Acad Sci.
281 Matam P, Kumaraiah V, Munichoodappa C, et al. (2000). Behavioural intervention in the management of compliance in young type-i diabetics. J Assoc Physicians India.
282 Mathis RA. (2014). The effect of exercise training intensity on physical fitness and physical function in people with type 2 diabetes: a randomized clinical trial. Dissertation Abstracts International: Section B: The Sciences and Engineering.
283 Mau MK, Glanz K, Severino R, et al. (2001). Mediators of lifestyle behavior change in native Hawaiians: initial findings from the native Hawaiian diabetes intervention program. Diabetes Care.
284 Mavros Y, Kay S, Simpson KA, et al. (2014). Reductions in c-reactive protein in older adults with type 2 diabetes are related to improvements in body composition following a randomized controlled trial of resistance training. J Cachexia Sarcopenia Muscle.
285 Mayer-Davis EJ, D'antonio A, Martin M, et al. (2001). Pilot study of strategies for effective weight management in type 2 diabetes: pounds off with empowerment (POWER). Fam Community Health.
286 Mazzuca KB, Farris NA, Mendenhall J, et al. (1997). Demonstrating the added value of community health nursing for clients with insulin-dependent diabetes. J Community Health Nurs.
287 Mccarrier KP, Ralston JD, Hirsch IB, et al. (2009). Web-based collaborative care for type 1 diabetes: a pilot randomized trial. Diabetes Technol Ther.
288 Mcginnis RA, Mcgrady A, Cox SA, et al. (2005). Biofeedback-assisted relaxation in type 2 diabetes. Diabetes Care.
289 Mckay HG, Glasgow RE, Feil EG, et al. (2002). Internet-based diabetes self-management and support: initial outcomes from the diabetes network project. Rehabil Psychol.
290 Mckay HG, King D, Eakin EG, et al. (2001). The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care.
291 Mclean DL, Mcalister FA, Johnson JA, et al. (2008). A randomized trial of the effect of community pharmacist and nurse care on improving blood pressure management in patients with diabetes mellitus: study of cardiovascular risk intervention by pharmacists-hypertension (SCRIP-Htn). Arch Intern Med.
292 Mcmahon GT, Fonda SJ, Gomes HE, et al. (2012). A randomized comparison of online- and telephone-based care management with internet training alone in adult patients with poorly controlled type 2 diabetes. Diabetes Technol Ther.
293 Mcmahon GT, Gomes HE, Hickson Hohne S, et al. (2005). Web-based care management in patients with poorly controlled diabetes. Diabetes Care.
294 Mehuys E, Van Bortel L, De Bolle L, et al. (2011). Effectiveness of a community pharmacist intervention in diabetes care: a randomized controlled trial. J Clin Pharm Ther.
295 Mendez FJ, Belendez M. (1997). Effects of a behavioral intervention on treatment adherence and stress management in adolescents with IDDM. Diabetes Care.
296 Mengham LH, Morris BF, Palmer CR, et al. (1999). Is intensive dietetic intervention effective for overweight patients with diabetes mellitus? A randomized controlled study in a general practice. Practical Diabetes International.
297 Middelkoop BJC, Geelhoed-Duijvestijn PHLM, Van Der Wal G. (2001). Effectiveness of culture-specific diabetes care for Surinam South Asian patients in the Hague: a randomized controlled trial/controlled before-and-after study. Diabetes Care.
298 Miller CK, Edwards L, Kissling G, et al. (2002). Nutrition education improves metabolic outcomes among older adults with diabetes mellitus: results from a randomized controlled trial. Prev Med.
299 Miller CK, Jensen GL, Achterberg CL. (1999). Evaluation of a food label nutrition intervention for women with type 2 diabetes mellitus. J Am Diet Assoc.
300 Mitra A, Dewanjee D, Dey B. (2012). Mechanistic studies of lifestyle interventions in type 2 diabetes. World J Diabetes.
301 Mollaoglu M, Beyazit E. (2009). Influence of diabetic education on patient metabolic control. Appl Nurs Res.
302 Mons U, Raum E, Kramer HU, et al. (2013). Effectiveness of a supportive telephone counseling intervention in type 2 diabetes patients: randomized controlled study. PLoS ONE.
303 Moskowitz D, Thom DH, Hessler D, et al. (2013). Peer coaching to improve diabetes self-management: which patients benefit most?. J Gen Intern Med.
304 Mulvaney SA, Rothman RL, Wallston KA, et al. (2010). An internet-based program to improve self-management in adolescents with type 1 diabetes. Diabetes Care.
305 Murphy HR, Wadham C, Hassler-Hurst J, et al. (2014). Randomized trial of a diabetes self-management education and family teamwork intervention in adolescents with type 1 diabetes. Diabet Med.
306 Naccashian Z. (2014). The impact of diabetes self-management education on glucose management and empowerment in ethnic Armenians with type 2 diabetes. Diabetes Educ.
307 Naik AD, Palmer N, Petersen NJ, et al. (2012). Comparative effectiveness of goal setting in diabetes mellitus group clinics: randomized clinical trial. Arch Intern Med.
308 Naik AD, Palmer N, Petersen NJ, et al. (2011). Comparative effectiveness of goal setting in diabetes mellitus group clinics: randomized clinical trial. Arch Intern Med.
309 Naik AD, White CD, Robertson SM, et al. (2012). Behavioral health coaching for rural-living older adults with diabetes and depression: an open pilot of the hope study. BMC Geriatr.
310 Nakamura N, Kanematsu Y. (1994). Coping in relation to self-care behaviors and control of blood glucose levels in japanese teenagers with insulin-dependent diabetes mellitus. J Pediatr Nurs.
311 Nebel IT, Klemm T, Fasshauer M, et al. (2004). Comparative analysis of conventional and an adaptive computer-based hypoglycaemia education programs. Patient Educ Couns.
312 New NF. (2007). The development and outcomes of a co-created diabetes self-management education intervention: a pilot study.
313 Newton KT. (2009). Impact of an interactive health communication application on promoting compliance in adolescents with type 1 diabetes. Dissertation Abstracts International Section A: Humanities and Social Sciences.
314 Nicholas DB, Fellner KD, Frank M, et al. (2012). Evaluation of an online education and support intervention for adolescents with diabetes. Soc Work Health Care.
315 Niswender K, Piletic M, Andersen H, et al. (2014). Weight change upon once-daily initiation of insulin detemir with or without dietary intervention in overweight or obese insulin-naive individuals with type 2 diabetes: results from the diet trial. Diabetes Obes Metab.
316 Niswender K, Piletic M, Andersen H, et al. (2014). Weight change upon once-daily initiation of insulin detemir with or without dietary intervention in overweight or obese insulin-naive individuals with type 2 diabetes: results from the diet trial. Diabetes Obes Metab.
317 Noda K, Zhang B, Iwata A, et al. (2012). Lifestyle changes through the use of delivered meals and dietary counseling in a single-blind study-the stylist study. Circ J.
318 Noel PH, Larme AC, Meyer J, et al. (1998). Patient choice in diabetes education curriculum. Nutritional versus standard content for type 2 diabetes. Diabetes Care.
319 Nothwehr FK, Guare J, Marrero DG, et al. (2001). Sequencing diet and exercise programs for African American women with diabetes. Diabetes Educ.
320 Nunn E, King B, Smart C, et al. (2006). A randomized controlled trial of telephone calls to young patients with poorly controlled type 1 diabetes. Pediatr Diabetes.
321 O'connor PJ, Desai J, Solberg LI, et al. (2005). Randomized trial of quality improvement intervention to improve diabetes care in primary care settings. Diabetes Care.
322 Ofstad AP, Johansen OE, Gullestad L, et al. (2014). Neutral impact on systolic and diastolic cardiac function of 2 years of intensified multi-intervention in type 2 diabetes: the randomized controlled asker and baerum cardiovascular diabetes (ABCD) study. Am Heart J.
323 Oh JA, Kim HS, Yoon KH, et al. (2003). A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J.
324 O'hare JP, Raymond NT, Mughal S, et al. (2004). Evaluation of delivery of enhanced diabetes care to patients of south asian ethnicity: the United Kingdom Asian Diabetes Study (UKADS). Diabet Med.
325 O'kane MJ, Bunting B, Copeland M, et al. (2008). Efficacy of self monitoring of blood glucose in patients with newly diagnosed type 2 diabetes (ESMON study): randomised controlled trial. BMJ.
326 Orsama AL, Lahteenmaki J, Harno K, et al. (2014). Active assistance technology reduces glycosylated hemoglobin and weight in individuals with type 2 diabetes: results of a theory-based randomized trial. Diabetes Technol Ther.
327 Osborn CY. (2006). Using the imb model of health behavior change to promote self-management behaviors in Puerto Ricans with diabetes. Dissertation Abstracts International Section A: Humanities and Social Sciences.
328 Palizgir M, Bakhtiyari M, Esteghamati A. (2014). Comparison between cognitive-behavioral therapy and psychoeducational therapy on blood sugar control in depressed patients with type 2 diabetes: a randomized clinical trail. Qom University of Medical Sciences Journal.
329 Panagiotopoulos C, Preston JM, Stewart LL, et al. (2003). Weekly telephone contact by a diabetes educator in adolescents with type 1 diabetes. Can.
330 Panagiotopoulos C, Stewart LL. (2003). Weekly telephone contact by a diabetes educator in adolescents with type 1 diabetes. Can.
331 Pandit AU, Bailey SC, Curtis LM, et al. (2014). Disease-related distress, self-care and clinical outcomes among low-income patients with diabetes. J Epidemiol Community Health.
332 Park SY, Lee IH. (2015). Effects on training and detraining on physical function, control of diabetes and anthropometrics in type 2 diabetes: a randomized controlled trial. Physiother Theory Pract.
333 Pascale RW, Wing RR, Butler BA, et al. (1995). Effects of a behavioral weight loss program stressing calorie restriction versus calorie plus fat restriction in obese individuals with NIDDM or a family history of diabetes. Diabetes Care.
334 Patton SR, Odar C, Midyett LK, et al. (2014). Pilot study results for a novel behavior plus nutrition intervention for caregivers of young children with type 1 diabetes. J Nutr Educ Behav.
335 Pena-Purcell NC, Boggess MM. (2014). An application of a diabetes knowledge scale for low-literate hispanic/latinos. Health Promot Pract.
336 Perez-Escamilla R, Damio G, Chhabra J, et al. (2014). Impact of a community health workers-led structured program on blood glucose control among Latinos with type 2 diabetes: the dialbest trial. Diabetes Care.
337 Perez-Tortosa S, Roig L, Manresa JM, et al. (2014). Continued smoking abstinence in diabetic patients in primary care: a cluster randomized controlled multicenter study. Diabetes Res Clin Pract.
338 Phumipamorn S, Pongwecharak J, Soorapan S, et al. (2008). Effects of the pharmacist's input on glycaemic control and cardiovascular risks in Muslim diabetes. Prim Care Diabetes.
339 Piatt GA, Orchard TJ, Emerson S, et al. (2006). Translating the chronic care model into the community: results from a randomized controlled trial of a multifaceted diabetes care intervention. Diabetes Care.
340 Pibernik-Okanovic M, Prasek M, Poljicanin-Filipovic T, et al. (2004). Effects of an empowerment-based psychosocial intervention on quality of life and metabolic control in type 2 diabetic patients. Patient Educ Couns.
341 Piette JD, Mcphee SJ, Weinberger M, et al. (1999). Use of automated telephone disease management calls in an ethnically diverse sample of low-income patients with diabetes. Diabetes Care.
342 Piette JD, Richardson C, Himle J, et al. (2011). A randomized trial of telephonic counseling plus walking for depressed diabetes patients. Med Care.
343 Piette JD, Weinberger M, Kraemer FB, et al. (2001). Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a department of veterans affairs health care system: a randomized controlled trial. Diabetes Care.
344 Piette JD, Weinberger M, Mcphee SJ. (2000). The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: a randomized, controlled trial. Med Care.
345 Plotnikoff RC, Karunamuni N, Courneya KS, et al. (2013). The Alberta diabetes and physical activity trial (ADAPT): a randomized trial evaluating theory-based interventions to increase physical activity in adults with type 2 diabetes. Ann Behav Med.
346 Polonsky WH, Earles J, Smith S, et al. (2003). Integrating medical management with diabetes self-management training: a randomized control trial of the diabetes outpatient intensive treatment program. Diabetes Care.
347 Puffelen AL, Rijken M, Nijpels G, et al. (2014). Group-based self-management support leads to more adequate exercise behaviour in recently diagnosed type 2 diabetes patients. Diabetologia.
348 Rachmani R, Slavacheski I, Berla M, et al. (2005). Treatment of high-risk patients with diabetes: motivation and teaching intervention: a randomized, prospective 8-year follow-up study. J Am Soc Nephrol.
349 Raji A, Gomes H, Beard JO, et al. (2002). A randomized trial comparing intensive and passive education in patients with diabetes mellitus. Arch Intern Med.
350 Rami B, Popow C, Horn W, et al. (2006). Telemedical support to improve glycemic control in adolescents with type 1 diabetes mellitus. Eur J Pediatr.
351 Raynor HA, Anderson AM, Miller GD, et al. (2015). Partial meal replacement plan and quality of the diet at 1 year: action for health in diabetes (Look Ahead) trial. J Acad Nutr Diet.
352 Reaney M, Zorzo EG, Golay A, et al. (2014). Impact of conversation map education tools versus regular care on diabetes-related knowledge of people with type 2 diabetes: a randomized, controlled study. Diabetes Spectr.
353 Redmon JB, Raatz SK, Reck KP, et al. (2003). One-year outcome of a combination of weight loss therapies for subjects with type 2 diabetes: a randomized trial. Diabetes Care.
354 Reilly CM, Higgins M, Butler J, et al. (2014). Cost effectiveness of an integrated self care intervention for persons with heart failure and diabetes. J Card Fail.
355 Rejeski WJ, Bray GA, Chen SH, et al. (2014). Aging and physical function in type 2 diabetes: 8 years of an intensive lifestyle intervention. J Gerontol A Biol Sci Med Sci.
356 Robertson JL. (2002). Evaluation of an andragogical intervention on the self-care behaviors of adults with non-insulin dependent diabetes mellitus.
357 Robison FF. (1993). A training and support group for elderly diabetics: description and evaluation. Journal for Specialists in Group Work.
358 Rosal MC, White MJ, Borg A, et al. (2010). Translational research at community health centers: challenges and successes in recruiting and retaining low-income Latino patients with type 2 diabetes into a randomized clinical trial. Diabetes Educ.
359 Rosenbek Minet LK, Wagner L, Lonvig EM, et al. (2011). The effect of motivational interviewing on glycaemic control and perceived competence of diabetes self-management in patients with type 1 and type 2 diabetes mellitus after attending a group education programme: a randomised controlled trial. Diabetologia.
360 Rosenberg D, Lin E, Peterson D, et al. (2014). Integrated medical care management and behavioral risk factor reduction for multicondition patients: behavioral outcomes of the teamcare trial. Gen Hosp Psychiatry.
361 Rossi MC, Nicolucci A, Di Bartolo P, et al. (2010). Diabetes interactive diary: a new telemedicine system enabling flexible diet and insulin therapy while improving quality of life: an open-label, international, multicenter, randomized study. Diabetes Care.
362 Rothman RL, Dewalt DA, Malone R, et al. (2004). Influence of patient literacy on the effectiveness of a primary care-based diabetes disease management program. JAMA.
363 Rothman RL, Malone R, Bryant B, et al. (2005). A randomized trial of a primary care-based disease management program to improve cardiovascular risk factors and glycated hemoglobin levels in patients with diabetes. Am J Med.
364 Rubak S, Sandbaek A, Lauritzen T, et al. (2011). Effect of “motivational interviewing” on quality of care measures in screen detected type 2 diabetes patients: a one-year follow-up of an rct, addition Denmark. Scand J Prim Health Care.
365 Rush TE. (2014). Assessing the efficacy of a culturally informed adherence intervention for rural African Americans with type 2 diabetes. Dissertation Abstracts International: Section B: The Sciences and Engineering.
366 Ryabov I. (2010). The impact of community health workers on behavioral outcomes and glycemic control of diabetes patients on the U.S.-Mexico border. Int Q Community Health Educ.
367 Ryabov I. (2014). Cost-effectiveness of community health workers in controlling diabetes epidemic on the U.S.-Mexico border. Public Health.
368 Ryden O, Nevander L, Johnsson P, et al. (1994). Family therapy in poorly controlled juvenile IDDM: effects on diabetic control, self-evaluation and behavioural symptoms. Acta Paediatr.
369 Rygg LO, Rise MB, Gronning K, et al. (2012). Efficacy of ongoing group based diabetes self-management education for patients with type 2 diabetes mellitus. a randomised controlled trial. Patient Educ Couns.
370 Sacco WP, Bykowski CA, Mayhew LL, et al. (2012). Educational attainment moderates the effect of a brief diabetes self-care intervention. Diabetes Res Clin Pract.
371 Sacre JW, Jellis CL, Jenkins C, et al. (2014). A six-month exercise intervention in subclinical diabetic heart disease: effects on exercise capacity, autonomic and myocardial function. Metabolism.
372 Sadler GR, Ko CM, Wu P, Ngai P. (2014). Lessons learned from the black cosmetologists promoting health program: a randomized controlled trial testing a diabetes education program. J Commun Healthc.
373 Sadur CN, Moline N, Costa M, et al. (1999). Diabetes management in a health maintenance organization. Efficacy of care management using cluster visits. Diabetes Care.
374 Saengtipbovorn S, Taneepanichskul S. (2014). Effectiveness of lifestyle change plus dental care (LCDC) program on improving glycemic and periodontal status in the elderly with type 2 diabetes. BMC Oral Health.
375 Safren SA, Gonzalez JS, Wexler DJ, et al. (2014). A randomized controlled trial of cognitive behavioral therapy for adherence and depression (CBT-AD) in patients with uncontrolled type 2 diabetes. Diabetes Care.
376 Saletsky RD, Trief PM, Anderson BJ, et al. (2014). Parenting style, parent-youth conflict, and medication adherence in youth with type 2 diabetes participating in an intensive lifestyle change intervention. Fam Syst Health.
377 Samaras K, Ashwell S, Mackintosh AM, et al. (1997). Will older sedentary people with non-insulin-dependent diabetes mellitus start exercising? A health promotion model. Diabetes Res Clin Pract.
378 Scain SF, Friedman R, Gross JL. (2009). A structured educational program improves metabolic control in patients with type 2 diabetes: a randomized controlled trial. Diabetes Educ.
379 Schillinger D, Handley M, Wang F, et al. (2009). Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial. Diabetes Care.
380 Schneider KL, Pagoto SL, Handschin B, et al. (2011). Design and methods for a pilot randomized clinical trial involving exercise and behavioral activation to treat comorbid type 2 diabetes and major depressive disorder. Ment Health Phy Act.
381 Schwedes U, Siebolds M, Mertes G. (2002). Meal-related structured self-monitoring of blood glucose: effect on diabetes control in non-insulin-treated type 2 diabetic patients. Diabetes Care.
382 Scott DM, Boyd ST, Stephan M, et al. (2006). Outcomes of pharmacist-managed diabetes care services in a community health center. Am J Health Syst Pharm.
383 Sears B, Kahl P, Rapier G. (2006). The San Antonio type 2 diabetic study. International Journal of Applied Kinesiology & Kinesiologic Medicine.
384 Shaya FT, Chirikov VV, Howard D, et al. (2014). Effect of social networks intervention in type 2 diabetes: a partial randomised study. J Epidemiol Community Health.
385 Shea S, Weinstock RS, Starren J, et al. (2006). A randomized trial comparing telemedicine case management with usual care in older, ethnically diverse, medically underserved patients with diabetes mellitus. J Am Med Inform Assoc.
386 Shechter A, St-Onge MP, Kuna ST, et al. (2014). Sleep architecture following a weight loss intervention in overweight and obese patients with obstructive sleep apnea and type 2 diabetes: relationship to apnea-hypopnea index. J Clin Sleep Med.
387 Shi Q, Ostwald SK, Wang S. (2010). Improving glycaemic control self-efficacy and glycaemic control behaviour in chinese patients with type 2 diabetes mellitus: randomised controlled trial. J Clin Nurs.
388 Siebolds M, Gaedeke O, Schwedes U. (2006). Self-monitoring of blood glucose-psychological aspects relevant to changes in hba1c in type 2 diabetic patients treated with diet or diet plus oral antidiabetic medication. Patient Educ Couns.
389 Silverman JB, Krieger J, Kiefer MM, et al. (2014). The association of food insecurity and diabetes control among low-income individuals. J Gen Intern Med.
390 Siminerio L, Ruppert K, Huber K, et al. (2014). Telemedicine for reach, education, access, and treatment (TREAT): linking telemedicine with diabetes self-management education to improve care in rural communities. Diabetes Educ.
391 Siminerio LM, Ruppert K, Emerson S, et al. (2008). Delivering diabetes self-management education (DSME) in primary care: the Pittsburgh regional initiative for diabetes education (PRIDE). Disease Management & Health Outcomes.
392 Simmons D, Fleming C, Voyle J, et al. (1998). A pilot urban church-based programme to reduce risk factors for diabetes among Western Samoans in New Zealand. Diabet Med.
393 Simmons D, Gamble GD, Foote S, et al. (2004). The New Zealand diabetes passport study: a randomized controlled trial of the impact of a diabetes passport on risk factors for diabetes-related complications. Diabet Med.
394 Sinclair AJ, Girling AJ, Gadsby R, et al. (2012). Diabetes in care homes: a cluster randomised controlled trial of resident education. British Journal of Diabetes and Vascular Disease.
395 Skoro-Kondza L, Tai SS, Gadelrab R, et al. (2009). Community based yoga classes for type 2 diabetes: an exploratory randomised controlled trial. BMC Health Serv Res.
396 Smith L, Weinert C. (2000). Telecommunication support for rural women with diabetes. Diabetes Educ.
397 Smith SM, Paul G, Kelly A, et al. (2011). Peer support for patients with type 2 diabetes: cluster randomised controlled trial. BMJ.
398 Snel M, Gastaldelli A, Ouwens DM, et al. (2012). Effects of adding exercise to a 16-week very low-calorie diet in obese, insulin-dependent type 2 diabetes mellitus patients. J Clin Endocrinol Metab.
399 Snoek FJ, Van Der Ven NCW, Twisk JWR, et al. (2008). Cognitive behavioural therapy (CBT) compared with blood glucose awareness training (BGAT) in poorly controlled type 1 diabetic patients: long-term effects on hba moderated by depression: a randomized controlled trial. Diabet Med.
400 Sone H, Katagiri A, Ishibashi S, et al. (2002). Effects of lifestyle modifications on patients with type 2 diabetes: the Japan diabetes complications study (JDCS) study design, baseline analysis and three year-interim report. Horm Metab Res.
401 Sone H, Tanaka S, Iimuro S, et al. (2010). Long-term lifestyle intervention lowers the incidence of stroke in Japanese patients with type 2 diabetes: a nationwide multicentre randomised controlled trial (the Japan diabetes complications study). Diabetologia.
402 Song M, Choe M, Kim KS, et al. (2009). An evaluation of web-based education as an alternative to group lectures for diabetes self-management. Nurs Health Sci.
403 Song M, Park Y, Song W, et al. (2012). Combined exercise training and self-management education for community-dwelling older adults with diabetes in Korea. J Gerontol Nurs.
404 Song MS, Kim HS. (2007). Effect of the diabetes outpatient intensive management programme on glycaemic control for type 2 diabetic patients. J Clin Nurs.
405 Souto DL, Zajdenverg L, Rodacki M, et al. (2014). Impact of advanced and basic carbohydrate counting methods on metabolic control in patients with type 1 diabetes. Nutrition.
406 Steed L, Barnard M, Hurel S, et al. (2014). How does change occur following a theoretically based self-management intervention for type 2 diabetes. Psychol Health Med.
407 Stuckey HL, Dellasega C, Graber NJ, et al. (2009). Diabetes nurse case management and motivational interviewing for change (dynamic): study design and baseline characteristics in the chronic care model for type 2 diabetes. Contemp Clin Trials.
408 Sturt JA, Whitlock S, Fox C, et al. (2008). Effects of the diabetes manual 1:1 structured education in primary care. Diabet Med.
409 Surwit RS, Van Tilburg MA, Zucker N, et al. (2002). Stress management improves long-term glycemic control in type 2 diabetes. Diabetes Care.
410 Svoren BM, Butler D, Levine BS, et al. (2003). Reducing acute adverse outcomes in youths with type 1 diabetes: a randomized, controlled trial. Pediatrics.
411 Tang PC, Overhage JM, Chan AS, et al. (2013). Online disease management of diabetes: engaging and motivating patients online with enhanced resources-diabetes (EMPOWER-D), a randomized controlled trial. J Am Med Inform Assoc.
412 Tao H, Sun XQ, He JH, et al. (2014). An interactive telemedicine system improves diabetes management for type 2 diabetic patients in China. Diabetes.
413 Tatti P, Lehmann ED. (2003). A prospective randomised-controlled pilot study for evaluating the teaching utility of interactive educational diabetes simulators. Diabetes Nutr Metab.
414 Taveira TH, Friedmann PD, Cohen LB, et al. (2010). Pharmacist-led group medical appointment model in type 2 diabetes. Diabetes Educ.
415 Taylor CB, Miller NH, Reilly KR, et al. (2003). Evaluation of a nurse-care management system to improve outcomes in patients with complicated diabetes. Diabetes Care.
416 Taylor DJ, Fletcher JP, Mathis RA, et al. (2014). Effects of moderate- versus high- intensity exercise training on physical fitness and physical function in people with type 2 diabetes: a randomized clinical trial. Phys Ther.
417 Taylor KI, Oberle KM, Crutcher RA, et al. (2005). Promoting health in type 2 diabetes: nurse-physician collaboration in primary care. Biol Res Nurs.
418 Thom D, Hessler D, Willard-Grace R, et al. (2014). Impact of health coaching on patient trust in their primary care provider: a randomized controlled trial. J Gen Intern Med.
419 Thom DH, Ghorob A, Hessler D, et al. (2013). Impact of peer health coaching on glycemic control in low-income patients with diabetes: a randomized controlled trial. Ann Fam Med.
420 Thom DH, Hessler D, Willard-Grace R, et al. (2014). Does health coaching change patients' trust in their primary care provider?. Patient Educ Couns.
421 Thoolen B, De Ridder D, Bensing J, et al. (2007). Who participates in diabetes self-management interventions? Issues of recruitment and retainment. Diabetes Educ.
422 Thoolen B, De Ridder D, Bensing J, et al. (2008). Beyond good intentions: the development and evaluation of a proactive self-management course for patients recently diagnosed with type 2 diabetes. Health Educ Res.
423 Tomar R, Hamdan M, Al-Qahtani MH. (2014). Effect of low to moderate intensity walking and cycling on glycaemic and metabolic control in type 1 diabetes mellitus adolescent males: a randomized controlled trial. Isokinet Exerc Sci.
424 Tomioka M, Braun KL, Ah Cook V, et al. (2014). Improving behavioral and clinical indicators in Asians and Pacific Islanders with diabetes: findings from a community clinic-based program. Diabetes Res Clin Pract.
425 Toobert DJ, Strycker LA, Barrera M, et al. (2010). Seven-year follow-up of a multiple-health-behavior diabetes intervention. Am J Health Behav.
426 Torbjornsen A, Jenum AK, Smastuen MC, et al. (2014). A low-intensity mobile health intervention with and without health counseling for persons with type 2 diabetes, part 1: baseline and short-term results from a randomized controlled trial in the Norwegian part of renewing health. JMIR MHealth and UHealth.
427 Tovote KA, Fleer J, Snippe E, et al. (2014). Individual mindfulness-based cognitive therapy and cognitive behavior therapy for treating depressive symptoms in patients with diabetes: results of a randomized controlled trial. Diabetes Care.
428 Trento M, Basile M, Borgo E, et al. (2008). A randomised controlled clinical trial of nurse-, dietitian- and pedagogist-led Group Care for the management of Type 2 diabetes. J Endocrinol Invest.
429 Trento M, Gamba S, Gentile L, et al. (2010). Rethink organization to improve education and outcomes (ROMEO): a multicenter randomized trial of lifestyle intervention by group care to manage type 2 diabetes. Diabetes Care.
430 Trento M, Passera P, Bajardi M, et al. (2002). Lifestyle intervention by group care prevents deterioration of type ii diabetes: a 4-year randomized controlled clinical trial. Diabetologia.
431 Trento M, Passera P, Borgo E, et al. (2005). A 3-year prospective randomized controlled clinical trial of group care in type 1 diabetes. Nutr Metab Cardiovasc Dis.
432 Trento M, Passera P, Borgo E, et al. (2004). A 5-year randomized controlled study of learning, problem solving ability, and quality of life modifications in people with type 2 diabetes managed by group care. Diabetes Care.
433 Trento M, Passera P, Tomalino M, et al. (2001). Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care.
434 Trento M, Passera P, Tomalino M, et al. (1998). Therapeutic group education in the follow-up of patients with non-insulin treated, non-insulin dependent diabetes mellitus. Diabetes Nutr Metab.
435 Trento M, Trinetta A, Kucich C, et al. (2011). Carbohydrate counting improves coping ability and metabolic control in patients with type 1 diabetes managed by group care. J Endocrinol Invest.
436 Trief PM, Izquierdo R, Eimicke JP, et al. (2013). Adherence to diabetes self care for white, African-American and Hispanic American telemedicine participants: 5 year results from the ideatel project. Ethn Health.
437 Trief PM, Sandberg J, Fisher L, et al. (2011). Challenges and lessons learned in the development and implementation of a couples-focused telephone intervention for adults with type 2 diabetes: the diabetes support project. Transl Behav Med.
438 Trief PM, Teresi JA, Izquierdo R, et al. (2007). Psychosocial outcomes of telemedicine case management for elderly patients with diabetes: the randomized ideatel trial. Diabetes Care.
439 Tu KS, Mcdaniel G, Gay JT. (1993). Diabetes self-care knowledge, behaviors, and metabolic control of older adults-the effect of a posteducational follow-up program. Diabetes Educ.
440 Tudor-Locke C, Bell RC, Myers AM, et al. (2004). Controlled outcome evaluation of the first step program: a daily physical activity intervention for individuals with type ii diabetes. Int J Obes Relat Metab Disord.
441 Tudor-Locke C, Lauzon N, Myers AM, et al. (2009). Effectiveness of the first step program delivered by professionals versus peers. J Phys Act Health.
442 Unick JL, Beavers D, Bond DS, et al. (2013). The long-term effectiveness of a lifestyle intervention in severely obese individuals. Am J Med.
443 Unick JL, Beavers D, Jakicic JM, et al. (2011). Effectiveness of lifestyle interventions for individuals with severe obesity and type 2 diabetes: results from the Look Ahead trial. Diabetes Care.
444 Uusitupa MI. (1996). Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Ann Med.
445 Vadstrup ES, Frolich A, Perrild H, et al. (2010). Lifestyle intervention by group-based rehabilitation versus individual counselling in type 2 diabetes: 1-year follow-up. Diabetologia.
446 Van Der Ven NCW, Hogenelst MHE, Tromp-Wever AME, et al. (2005). Short-term effects of cognitive behavioural group training (CBGT) in adult type 1 diabetes patients in prolonged poor glycaemic control: a randomized controlled trial. Diabet Med.
447 Van Dyck D, De Greef K, Deforche B, et al. (2011). Mediators of physical activity change in a behavioral modification program for type 2 diabetes patients. Int.
448 Van Son J, Nyklicek I, Pop VJ, et al. (2014). Mindfulness-based cognitive therapy for people with diabetes and emotional problems: long-term follow-up findings from the diamind randomized controlled trial. J Psychosom Res.
449 Van Veldhuizen-Scott MK, Widmer LB, Stacey SA, et al. (1995). Developing and implementing a pharmaceutical care model in an ambulatory care setting for patients with diabetes. Diabetes Educ.
450 Vanninen E, Laitinen J, Uusitupa M. (1994). Physical activity and fibrinogen concentration in newly diagnosed NIDDM. Diabetes Care.
451 Vanninen E, Uusitupa M, Lansimies E, et al. (1993). Effect of metabolic control on autonomic function in obese patients with newly diagnosed type 2 diabetes. Diabet Med.
452 Varroud-Vial M, Simon D, Attali J, et al. (2004). Improving glycaemic control of patients with type 2 diabetes in a primary care setting: a French application of the staged diabetes management programme. Diabet Med.
453 Venmans LMaJ, Gorter KJ, Hak E, et al. (2008). Short-term effects of an educational program on health-seeking behavior for infections in patients with type 2 diabetes: a randomized controlled intervention trial in primary care. Diabetes Care.
454 Verrotti A, Chiarelli F, Sabatino G, et al. (1993). Education, knowledge and metabolic control in children with type 1 diabetes. Riv Eur Sci Med Farmacol.
455 Viklund GE, Rudberg S, Wikblad KF. (2007). Teenagers with diabetes: self-management education and training on a big schooner. Int J Nurs Pract.
456 Vincent D. (2009). Culturally tailored education to promote lifestyle change in Mexican Americans with type 2 diabetes. J Am Acad Nurse Pract.
457 Vries L, Heijden AA, Baan CA, et al. (2014). Effects of peer support in type 2 diabetes patients on diabetes related distress, self efficacy and well being: a randomised controlled trial. Diabetologia.
458 W Hutchison R. (2014). Treating diabetes in underserved populations using an interprofessional care team. J Interprof Care.
459 Wadden TA, Neiberg RH, Wing RR, et al. (2011). Four-year weight losses in the Look Ahead study: factors associated with long-term success. Obesity (Silver Spring).
460 Wadham C, Hassler Hurst J, Almond J, et al. (2005). Integrating group education into paediatric diabetes care: facts. J Diabetes Nurs.
461 Wagnild G, Maccart JG, Mitchell S, et al. (2008). A telecommunications intervention for frontier patients with diabetes. Telemed J E Health.
462 Walders-Abramson N, Venditti EM, Ievers-Landis CE, et al. (2014). Relationships among stressful life events and physiological markers, treatment adherence, and psychosocial functioning among youth with type 2 diabetes. J Pediatr.
463 Walford GA, Ma Y, Christophi CA, et al. (2014). Circulating natriuretic peptide concentrations reflect changes in insulin sensitivity over time in the diabetes prevention program. Diabetologia.
464 Walker EA, Stevens KA, Persaud S. (2010). Promoting diabetes self-management among African Americans: an educational intervention. J Health Care Poor Underserved.
465 Wallace A, Perkhounkova Y, Tseng H, et al. (2013). Influence of patient characteristics on assessment of diabetes self-management support. Nurs Res.
466 Wang ML, Gellar L, Nathanson BH, et al. (2014). Decrease in glycemic index associated with improved glycemic control among Latinos with type 2 diabetes. J Acad Nutr Diet.
467 Wang Y, Stewart SM, Mackenzie M, et al. (2010). A randomized controlled trial comparing motivational interviewing in education to structured diabetes education in teens with type 1 diabetes. Diabetes Care.
468 Webb PM. (1999). The impact of parental involvement in goal setting on treatment adherence for children with insulin-dependent diabetes mellitus.
469 Weinberger M, Kirkman MS, Samsa GP, et al. (1995). A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Intern Med.
470 Weinstock RS, Brooks G, Palmas W, et al. (2011). Lessened decline in physical activity and impairment of older adults with diabetes with telemedicine and pedometer use: results from the ideatel study. Age Ageing.
471 Weinstock RS, Teresi JA, Goland R, et al. (2011). Glycemic control and health disparities in older ethnically diverse underserved adults with diabetes: five-year results from the informatics for diabetes education and telemedicine (ideatel) study. Diabetes Care.
472 Welch G, Allen NA, Zagarins SE, et al. (2011). Comprehensive diabetes management program for poorly controlled Hispanic type 2 patients at a community health center. Diabetes Educ.
473 West SP, Lagua C, Trief PM, et al. (2010). Goal setting using telemedicine in rural underserved older adults with diabetes: experiences from the informatics for diabetes education and telemedicine project. Telemed J E Health.
474 Westman EC. (2014). In overweight or obese patients with diabetes, a lifestyle intervention increased weight loss at 8 years. Ann Intern Med.
475 Westrupp E, Northam E, Lee K, et al. (2014). Reducing and preventing internalizing and externalizing behavior problems in children with type 1 diabetes: a randomized controlled trial of the triple p-positive parenting program. Pediatr Diabetes.
476 Wheeler ML. (2005). Translation of successful diabetes-related lifestyle interventions from research to practice. Curr Diab Rep.
477 Whittemore R, Grey M, Lindemann E, et al. (2010). Development of an internet coping skills training program for teenagers with type 1 diabetes. Comput Inform Nurs.
478 Whittemore R, Melkus GD, Sullivan A, et al. (2004). A nurse-coaching intervention for women with type 2 diabetes. Diabetes Educ.
479 Wildermuth SA. (2008). Cognitive behavioral group therapy for adolescents with type i diabetes. Dissertation Abstracts International: Section B: The Sciences and Engineering.
480 Williams GC, Mcgregor H, Zeldman A, et al. (2005). Promoting glycemic control through diabetes self-management: evaluating a patient activation intervention. Patient Educ Couns.
481 Williams IC, Utz SW, Hinton I, et al. (2014). Enhancing diabetes self-care among rural African Americans with diabetes: results of a two-year culturally tailored intervention. Diabetes Educ.
482 Williamson DA, Rejeski J, Lang W, et al. (2009). Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Arch Intern Med.
483 Wing RR, Anglin K. (1996). Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care.
484 Wing RR, Blair E, Marcus M, et al. (1994). Year-long weight loss treatment for obese patients with type ii diabetes: does including an intermittent very-low-calorie diet improve outcome?. Am J Med.
485 Wing RR, Leahey T, Jeffery R, et al. (2014). Do weight loss and adherence cluster within behavioral treatment groups?. Obesity (Silver Spring).
486 Wing RR, Shiffman S, Drapkin RG, et al. (1995). Moderate versus restrictive diets: implications for relapse. Behav.
487 Wisse W, Rookhuizen MB, De Kruif MD, et al. (2010). Prescription of physical activity is not sufficient to change sedentary behavior and improve glycemic control in type 2 diabetes patients. Diabetes Res Clin Pract.
488 Woe SK, Sakano Y. (1996). Cognitive-behavioral intervention to chronic disease patients. Japanese Journal of Psychosomatic Medicine.
489 Wolf MS, Seligman H, Davis TC, et al. (2014). Clinic-based versus outsourced implementation of a diabetes health literacy intervention. J Gen Intern Med.
490 Wolf MS, Seligman H, Davis TC, et al. (2014). Clinic-based versus outsourced implementation of a diabetes health literacy intervention. J Gen Intern Med.
491 Wylie-Rosett J. (2014). Weight-loss intervention by telephone: lessons learned. Diabetes Care.
492 Wysocki T, Greco P, Harris MA, et al. (2001). Behavior therapy for families of adolescents with diabetes: maintenance of treatment effects. Diabetes Care.
493 Wysocki T, Harris MA, Buckloh LM, et al. (2008). Randomized, controlled trial of behavioral family systems therapy for diabetes: maintenance and generalization of effects on parent-adolescent communication. Behav.
494 Wysocki T, Harris MA, Greco P, et al. (2000). Randomized, controlled trial of behavior therapy for families of adolescents with insulin-dependent diabetes mellitus. J Pediatr Psychol.
495 Wysocki T, Harris MA, Wilkinson K, et al. (2003). Self-management competence as a predictor of outcomes of intensive therapy or usual care in youth with type 1 diabetes. Diabetes Care.
496 Yamada Y, Uchida J, Izumi H, et al. (2014). A non-calorie-restricted low-carbohydrate diet is effective as an alternative therapy for patients with type 2 diabetes. Intern Med.
497 Yamauchi K, Katayama T, Yamauchi T, et al. (2014). Efficacy of a 3-month lifestyle intervention program using a japanese-style healthy plate on body weight in overweight and obese diabetic Japanese subjects: a randomized controlled trial. Nutr J.
498 Yannakoulia M, Poulia KA, Mylona E, et al. (2007). Effectiveness of an intensive nutritional intervention in patients with type 2 diabetes mellitus: results from a pilot study. Rev Diabet Stud.
499 Yoo HJ, Park MS, Kim TN, et al. (2009). A ubiquitous chronic disease care system using cellular phones and the internet. Diabet Med.
500 Yopp JM. (2005). The impact of family functioning on treatment adherence and metabolic control for adolescents with poorly controlled type 1 diabetes. Dissertation Abstracts International: Section B: The Sciences and Engineering.
501 Young H, Miyamoto S, Ward D, et al. (2014). Sustained effects of a nurse coaching intervention via telehealth to improve health behavior change in diabetes. Telemed J E Health.
502 Young RJ, Taylor J, Friede T, et al. (2005). Proactive call center treatment support (PACCTS) to improve glucose control in type 2 diabetes: a randomized controlled trial. Diabetes Care.
503 Zapotoczky H, Semlitsch B, Herzog G, et al. (2001). A controlled study of weight reduction in type 2 diabetics treated by two reinforcers. Int J Behav Med.
504 Zolfaghari M, Mousavifar SA, Pedram S, et al. (2012). The impact of nurse short message services and telephone follow-ups on diabetic adherence: which one is more effective?. J Clin Nurs.