# Appendix C Very High Human Development Index Countries

These countries meet the category of Very-high Human Development Index status, as per the United Nations Development Program. (Human Development Report 2013 Team. Table 1. Human Development Index and its components. In: Human Development Report 2013. The Rise of the South: Human Progress in a Diverse World. United Nations Development Programme, 2013; pp 144-7. http://hdr.undp.org/en/content/human-development-report-2013. Accessed March 3, 2014.)

Andorra

Argentina

Australia

Austria

Barbados

Belgium

Brunei Darussalam

Canada

Chile

Croatia

Cyprus

Czech Republic

Denmark

Estonia

Finland

France

Germany

Greece

Hong Kong, China (SAR)

Hungary

Iceland

Ireland

Israel

Italy

Japan

Korea (Republic of)

Latvia

Liechtenstein

Lithuania

Luxembourg

Malta

Netherlands

New Zealand

Norway

Poland

Portugal

Qatar

Seychelles

Singapore

Slovakia

Slovenia

Spain

Sweden

Switzerland

United Arab Emirates

United Kingdom

United States