# Appendix B Literature Search Strategies

## MEDLINE

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present

Search Title: Behavioral Health Programs for Diabetes_1

Search Date: 28 May 2014

Results: 15064

1. exp Diabetes Mellitus/
2. exp hypoglycemia/
3. diabet*.mp.
4. (noninsulin depend* or non insulin depend* or insulin depend*).mp.
5. (T1DM or T2DM or IDDM or NIDDM).mp.
6. or/1-5
7. exp Diabetes Insipidus/
8. (diabet* adj3 (insipidus not mellitus)).mp.
9. or/7-8
10. 6 not 9 (473318)
11. Behavior Therapy/
12. Blood Glucose Self-Monitoring/
13. Cognitive Therapy/
14. Community Health Centers/
15. Disease Management/
16. exp Exercise/ and (counsel* or intervention* or program* or train*).mp.
17. exp Exercise Therapy/
18. exp Directive Counseling/
19. Health Behavior/ and (counsel* or intervention* or program* or train*).mp.
20. Health Education/
21. Health Promotion/
22. exp Nutrition Therapy/
23. “Outcome Assessment (Health Care)”/
24. exp Patient Care Team/
25. exp Patient Compliance/
26. Patient Education as Topic/
27. Program Evaluation/
28. Relaxation Therapy/
29. Self Administration/
30. Self Medication/
31. Self Care/
32. Weight Loss/
33. (behavio?r adj2 therap*).mp.
34. (blood glucose adj2 monitor*).mp.
35. (cognitive adj2 therap*).mp.
36. (communit* adj2 (center* or centre*)).mp.
37. disease management.mp.
38. directive counsel*.mp.
39. ((behavio* or exercis* or diet* or fitness or life style* or lifestyle* or nutrition or physical activit* or problem solving or relax*) adj3 (counsel* or intervention* or program* or therap* or train* or treat*)).mp.
40. motivation* interview*.mp.
41. (self manag* or selfmanag* or self car* or selfcar*).mp.
42. or/11-41 (655126)
43. 10 and 42 (43958)
44. randomized controlled trial.pt.
45. controlled clinical trial.pt.
46. randomi?ed.ab.
47. placebo.ab.
48. drug therapy.fs.
49. randomly.ab.
50. trial.ab.
51. groups.ab.
52. or/44-51
53. exp animals/ not humans.sh.
54. 52 not 53
55. 43 and 54 (16442)
56. cohort studies/
57. follow-up studies/
58. longitudinal studies/
59. prospective studies/
60. cohort analy*.tw.
61. (cohort adj (study or studies)).tw.
62. (control* adj5 (before adj2 after)).tw.
63. (control* adj5 (pre* adj2 post*)).tw.
64. (follow up adj (study or studies)).tw.
65. longitudinal.tw.
66. (observational adj (study or studies)).tw.
67. prospective.tw.
68. or/56-67 (1252385)
69. exp animals/ not humans.sh.
70. 68 not 69
71. 43 and 70 (5831)
72. 55 or 71 (19002)
73. limit 72 to yr=“1993-2014” (16423)
74. limit 73 to english language (15064)

## CENTRAL

Database: CENTRAL via Cochrane Library

Search Title: Behavioral Health Programs for Diabetes

Date Searched: 30 May 2014

Results: 8010

1. MeSH descriptor: [Diabetes Mellitus] explode all trees
2. MeSH descriptor: [Hypoglycemia] explode all trees
3. diabet*:ti,ab,kw
4. (“noninsulin depend*” or “non insulin depend*” or “insulin depend*”):ti,ab,kw
5. (T1DM or T2DM or IDDM or NIDDM):ti,ab,kw
6. #1 or #2 or #3 or #4 or #5
7. exp Diabetes Insipidus/
8. (diabet* near/3 (insipidus not mellitus)):ti,ab,kw
9. #7 or #8
10. #6 not #9 (31905)
11. MeSH descriptor: [Behavior Therapy] this term only
12. MeSH descriptor: [Blood Glucose Self-Monitoring] this term only
13. MeSH descriptor: [Cognitive Therapy] this term only
14. MeSH descriptor: [Community Health Centers] this term only /
15. MeSH descriptor: [Disease Management] this term only
16. MeSH descriptor: [Exercise] explode all trees
17. (counsel* or intervention* or program* or train*):ti,ab,kw
18. #16 and #17
19. MeSH descriptor: [Exercise Therapy] explode all trees
20. MeSH descriptor: [Directive Counseling] explode all trees
21. MeSH descriptor: [Health Behavior] this term only
22. (counsel* or intervention* or program* or train*):ti,ab,kw
23. #21 and #22
24. MeSH descriptor: [Health Education] this term only
25. MeSH descriptor: [Health Promotion] this term only
26. MeSH descriptor: [Nutrition Therapy] explode all trees
27. MeSH descriptor: [Outcome Assessment (Health Care)] this term only
28. MeSH descriptor: [Patient Care Team] explode all trees
29. MeSH descriptor: [Patient Compliance] explode all trees
30. MeSH descriptor: [Patient Education as Topic] this term only
31. MeSH descriptor: [Program Evaluation] this term only
32. MeSH descriptor: [Relaxation Therapy] this term only
33. MeSH descriptor: [Self Administration] this term only
34. MeSH descriptor: [Self Medication] this term only
35. MeSH descriptor: [Self Care] this term only
36. MeSH descriptor: [Weight Loss] this term only
37. (behavio*r near/2 therap*):ti,ab,kw
38. (“blood glucose” near/2 monitor*):ti,ab,kw
39. (cognitive near/2 therap*):ti,ab,kw
40. (communit* near/2 (center* or centre*)):ti,ab,kw
41. “disease management”:ti,ab,kw
42. “directive counsel*”:ti,ab,kw
43. ((behavio* or exercis* or diet* or fitness or “life style*” or lifestyle* or nutrition or “physical activit*” or “problem solving” or relax*) near/3 (counsel* or intervention* or program* or therap* or train* or treat*)):ti,ab,kw
44. “motivation* interview*”:ti,ab,kw
45. (“self manag*” or selfmanag* or “self car*” or selfcar*):ti,ab,kw
46. #11 or #12 or #13 or 14 or #15 or #18 or #19 or #20 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 (175091)
47. #10 and #46 (9944)

limit: Publication Date from 1993 to 2014, in Trials (8010)

## CINAHL

Database: CINAHL

Search Title: Behavioral Health Programs for Diabetes

Date Searched: 30 May 2014

Results: 8881

1 (MH “Diabetes Mellitus+”)
2 (MH “Hypoglycemia+”)
3 diabet*
4 “noninsulin depend*” or “non insulin depend*” or “insulin depend*”
5 T1DM or T2DM or IDDM or NIDDM
6 S1 OR S2 OR S3 OR S4 OR S5
7 (MH “Diabetes Insipidus+”)
8 diabet* N3 (insipidus not mellitus)
9 S7 OR S8
10 S6 not S9 (120,132)
11 (MH “Behavior Therapy”)
12 (MH “Blood Glucose Self-Monitoring”)
13 (MH “Cognitive Therapy”)
14 (MH “Community Health Centers”)
15 (MH “Diabetes Education”)
16 (MH “Diet Therapy+”)
17 (MH “Disease Management”)
18 (MH “Exercise+”) AND (counsel* or intervention* or program* or train*)
19 (MH “Health Behavior”) AND (counsel* or intervention* or program* or train*)
20 (MH “Health Education”)
21 (MH “Health Promotion”)
22 (MH “Motivational Interviewing”)
23 (MH “Multidisciplinary Care Team+”)
24 (MH “Outcome Assessment”)
25 (MH “Patient Compliance+”)
26 (MH “Patient Education”)
27 (MH “Program Evaluation”)
28 (MH “Self Administration”)
29 (MH “Self Medication”)
30 (MH “Self Care”)
31 (MH “Therapeutic Exercise+”)
32 (MH “Weight Loss”)
33 behavio#r N2 therap*
35 “blood glucose” N2 monitor*
36 cognitive N2 therap*
36 communit* N2 (center* or centre*)
37 “disease management”
38 “directive counsel*”
39 (behavio* or exercis* or diet* or fitness or “life style*” or lifestyle* or nutrition or “physical activit*” or “problem solving” or relax*) N3 (counsel* or intervention* or program* or therap* or train* or treat*)
40 “motivation* interview*”
41 “self manag*” or selfmanag* or “self car*” or selfcar*
42 S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 (334531)
43 S10 AND S42 (27139)
44 (MH “Clinical Trials+”)
45 PT Clinical trial
46 TX clinic* n1 trial*
47 TX ( (singl* n1 blind*) or (singl* n1 mask*) ) or TX ( (doubl* n1 blind*) or (doubl* n1 mask*) ) or TX ( (tripl* n1 blind*) or (tripl* n1 mask*) ) or TX ( (trebl* n1 blind*) or (trebl* n1 mask*) )
48 TX randomi* control* trial*
49 (MH “Random Assignment”)
50 TX random* allocat*
51 TX placebo*
52 (MH “Placebos”)
53 (MH “Quantitative Studies”)
54 TX allocat* random*
53 (MH “Quantitative Studies”)
54 TX allocat* random*
55 S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54
56 (MH “Animals+”) NOT (MH “Human”)
57 S55 NOT S56
58 S43 AND S57 (7921)
59 (MH “Concurrent Prospective Studies”)
60 (MH “Nonexperimental Studies”)
61 (MH “Prospective Studies”)
62 “cohort analy*”
63 cohort N1 (study or studies)
64 control* N5 (before N2 after)
65 control* N5 (pre* N2 post*)
66 “follow up” N1 (study or studies)
67 longitudinal
68 observational N1 (study or studies)
69 prospective
70 S59 OR S60 OR S61 OR S62 OR S63 OR S64 OR S65 OR S66 OR S67 OR S68 OR S69
71 (MH “Animals+”) NOT (MH “Human”)
72 S70 not S71
73 S43 AND S72 (2627)
74 S58 OR S73 (9468)
75 S74 Limiters – English Language; Publication Date: 19930101-20141231 (8881)

## Ovid Embase

Database: Ovid Embase 1988 to 2014 Week 21

Search Title: Behavioral Health Programs for Diabetes_2

Date Searched: May 29, 2014

Results: 24629

1. exp diabetes mellitus/
2. exp hypoglycemia/
3. diabet*.mp.
4. (noninsulin depend* or non insulin depend* or insulin depend*).mp.
5. (T1DM or T2DM or IDDM or NIDDM).mp.
6. or/1-5
7. exp diabetes insipidus/
8. (diabet* adj3 (insipidus not mellitus)).mp.
9. or/7-8
10. 6 not 9 (613880)
11. behavior therapy/
12. blood glucose monitoring/
13. cognitive therapy/
14. diabetes education/
15. exp diet therapy/
16. directive counseling/
17. disease management/
18. drug self administration/
19. exp Exercise/ and (counsel* or intervention* or program* or train*).mp.
20. Health Behavior/ and (counsel* or intervention* or program* or train*).mp.
21. health center/
22. health education/
23. health promotion/
24. exp kinesiotherapy/
25. nutrition education/
26. outcome assessment/
27. patient care/
28. exp patient compliance/
29. patient education/
30. exp program evaluation/
31. rapid response team/
32. relaxation training/
33. self care/
34. weight reduction/
35. (behavio?r adj2 therap*).mp.
36. (blood glucose adj2 monitor*).mp.
37. (cognitive adj2 therap*).mp.
38. (communit* adj2 (center* or centre*)).mp.
39. disease management.mp.
40. directive counsel*.mp.
41. ((behavio* or exercis* or diet* or fitness or life style* or lifestyle* or nutrition or physical activit* or problem solving or relax*) adj3 (counsel* or intervention* or program* or therap* or train* or treat*)).mp.
42. motivation* interview*.mp.
43. (self manag* or selfmanag* or self car* or selfcar*).mp.
44. or/11-43 (1217935)
45. 10 and 44 (121429)
46. random*.mp.
47. animals/ not (animals/ and humans/)
48. 46 not 47
49. 45 and 48 (18450)
50. cohort analysis/
51. longitudinal study/
52. prospective study/
53. (cohort adj (study or studies)).tw.
54. (control* adj5 (before adj2 after)).tw.
55. (control* adj5 (pre* adj2 post*)).tw.
56. (follow up adj (study or studies)).tw.
57. (prospective adj (study or studies)).tw.
58. or/50-57
59. animals/ not (animals/ and humans/)
60. 58 not 59
61. 45 and 60 (9212)
62. 49 or 61 (25875)
63. limit 62 to yr=“1993-2014” (25632)
64. limit 63 to english language (24629)

## Ovid PsycINFO

Database: Ovid PsycINFO 1987 to May Week 4 2014

Search Title: Behavioral Health Programs for Diabetes_3

Date Searched: 29 May 2014

Results: 4008

1. exp Diabetes/
2. Hypoglycemia/
3. diabet*.mp.
4. (noninsulin depend* or non insulin depend* or insulin depend*).mp.
5. (T1DM or T2DM or IDDM or NIDDM).mp.
6. or/1-5
7. Diabetes Insipidus/
8. (diabet* adj3 (insipidus not mellitus)).mp.
9. or/7-8
10. 6 not 9 (18569)
11. Behavior Therapy/
12. Client Centered Therapy/
13. Client Education/
14. Cognitive Therapy/
15. exp Community Services/
16. exp Compliance/
17. exp Counseling/
18. Disease Management/
19. Drug Self Administration/
20. exp Exercise/ and (counsel* or intervention* or program* or train*).mp.
21. Health Behavior/ and (counsel* or intervention* or program* or train*).mp.
22. exp Health Care Delivery/
23. Health Care Services/
24. Health Education/
25. Health Promotion/
26. Movement Therapy/
27. Motivational Interviewing/
28. Physical Activity/
29. exp Program Evaluation/
30. Recreation Therapy/
31. exp Relaxation Therapy/
32. Self Monitoring/
33. Self Care Skills/
34. Weight Control/
35. Weight Gain/
36. Weight Loss/
37. (behavio?r adj2 therap*).mp.
38. (blood glucose adj2 monitor*).mp.
39. (cognitive adj2 therap*).mp.
40. (communit* adj2 (center* or centre*)).mp.
41. disease management.mp.
42. directive counsel*.mp.
43. ((behavio* or exercis* or diet* or fitness or life style* or lifestyle* or nutrition or physical activit* or problem solving or relax*) adj3 (counsel* or intervention* or program* or therap* or train* or treat*)).mp.
44. motivation* interview*.mp.
45. (self manag* or selfmanag* or self car* or selfcar*).mp.
46. or/11-45 (258474)
47. 10 and 46 (5964)
48. control*.tw.
49. random*.tw.
50. exp treatment/
51. or/ 48-50
52. exp animals/ not humans.sh.
53. 51 not 52
54. 47 and 53 (4248)
55. cohort analy*.tw.
56. (cohort adj (study or studies)).tw.
57. (control* adj5 (before adj2 after)).tw.
58. (control* adj5 (pre* adj2 post*)).tw.
59. (follow up adj (study or studies)).tw.
60. longitudinal.tw.
61. (observational adj (study or studies)).tw.
62. prospective.tw.
63. or/55-62
64. exp animals/ not humans.sh.
65. 63 not 64
66. 47 and 65 (502)
67. 54 or 66 (4367)
68. limit 67 to yr=“1993-2014” (4103)
69. limit 68 to english language (4010)
70. remove duplicates from 69 (4008)

## PubMed

Database: PubMed

Search Title:

Date Searched: 30 May 2014

Results: 670

1. “Diabetes Mellitus”[Mesh]
2. “Hypoglycemia”[Mesh]
3. diabet*[tiab]
4. “noninsulin dependent”[tiab] OR “non insulin dependent”[tiab] OR “insulin dependent”[tiab]
5. T1DM[tiab] OR T2DM[tiab] OR IDDM[tiab] OR NIDDM[tiab]
6. #1 OR #2 OR #3 OR #4 OR #5
7. “Diabetes Insipidus”[Mesh]
8. diabet*[tiab] AND (insipidus[tiab] NOT mellitus[tiab])
9. #7 OR #8
10. #6 NOT #9 (472248)
11. “Behavior Therapy”[Mesh:NoExp]
12. “Blood Glucose Self-Monitoring”[Mesh]
13. “Cognitive Therapy”[Mesh:NoExp]
14. “Community Health Centers”[Mesh:NoExp]
15. “Disease Management”[Mesh:NoExp]
16. “Exercise”[Mesh] AND (counsel* or intervention* or program* or train*)
17. “Exercise Therapy”[Mesh]
18. “Directive Counseling”[Mesh]
19. “Health Behavior”[Mesh] AND (counsel* or intervention* or program* or train*)
20. “Health Education”[Mesh:NoExp]
21. “Health Promotion”[Mesh:NoExp]
22. “Nutrition Therapy”[Mesh]
23. “Outcome Assessment (Health Care)”[Mesh:NoExp]
24. “Patient Care Team”[Mesh]
25. “Patient Compliance”[Mesh]
26. “Patient Education as Topic”[Mesh:NoExp]
27. “Program Evaluation”[Mesh:NoExp]
28. “Relaxation Therapy”[Mesh:NoExp]
29. “Self Administration”[Mesh]
30. “Self Medication”[Mesh] /
31. “Self Care”[Mesh:NoExp]
32. “Weight Loss”[Mesh:NoExp]
33. “behavior therapy”[tiab] OR “behaviour therapy”[tiab] OR “behavior therapies”[tiab] OR “behaviour therapies”[tiab] OR “behavioral therapy”[tiab] OR “behavioural therapy”[tiab] OR “behavioral therapies”[tiab] OR “behavioural therapies”[tiab]
34. “blood glucose monitoring”[tiab]
35. “cognitive therapy”[tiab] OR “cognitive therapies”[tiab]
36. “community centre”[tiab] OR “community centres”[tiab] OR “community center”[tiab] OR “community centers”[tiab]
37. “disease management”[All Fields]
38. “directive counseling”[All Fields]
39. ((behavio*[tiab] or exercis*[tiab] or diet[tiab] or fitness[tiab] or “life style”[tiab] or “life styles”[tiab] or lifestyle*[tiab] or nutrition[tiab] or “physical activity”[tiab] or “problem solving”[tiab] or relax*[tiab]) AND (counsel*[tiab] or intervention*[tiab] or program*[tiab] or therap*[tiab] or train*[tiab] or treat*[tiab]))
40. “motivational interviewing”[tiab] OR “motivational interview”[tiab] OR “motivational interviews”[tiab]
41. “self manage”[tiab] OR “self managed”[tiab] OR selfmanag*[tiab] or “self care”[tiab] or selfcar*[tiab]
42. #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 (965205)
43. #10 AND #42 (56413)
44. randomized controlled trial [pt]
45. controlled clinical trial [pt]
46. randomized [tiab]
47. placebo [tiab]
48. drug therapy [sh]
49. randomly [tiab]
50. trial [tiab]
51. groups [tiab]
52. #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51
53. animals [mh] NOT humans [mh]
54. #52 NOT #53
55. #43 AND #54 (20350)
56. “Cohort Studies”[Mesh:NoExp]
57. “Follow-Up Studies”[Mesh]
58. “Longitudinal Studies”[Mesh:NoExp]
59. “Prospective Studies”[Mesh]
60. “cohort analysis”[tiab] OR “cohort analyses”[tiab]
61. “cohort study”[tiab] OR “cohort studies”[tiab]
62. “controlled before and after”[tiab] OR “controlled before after”[tiab]
63. control*[tiab] AND pre[tiab] AND post[tiab] AND (study[tiab] OR studies[tiab])
64. “follow up study”[tiab] OR “follow up studies”[tiab]
65. longitudinal[tiab]
66. “observational study”[tiab] OR “observational studies”[tiab]
67. prospective[tiab]
68. #56 OR #57 OR #58 OR #59 OR #60 OR #61 OR #62 OR #63 OR #64 OR #65 OR #66 OR #67
69. animals [mh] NOT humans [mh]
70. #68 NOT #69
71. #43 AND #70 (7284)
72. #55 OR #71 (23770)
73. #72 Filters activated: Publication date from 2014/01/01 to 2014/12/31 (685)
74. #73 Filters activated: English (670)

Single search string:

Search: (((((“Diabetes Mellitus”[Mesh]) OR (“Hypoglycemia”[Mesh]) OR (diabet*[tiab]) OR (“noninsulin dependent”[tiab] OR “non insulin dependent”[tiab] OR “insulin dependent”[tiab]) OR (T1DM[tiab] OR T2DM[tiab] OR IDDM[tiab] OR NIDDM[tiab])) NOT ((diabet*[tiab] AND (insipidus[tiab] NOT mellitus[tiab])) OR (“Diabetes Insipidus”[Mesh]))) AND ((“self manage”[tiab] OR “self managed”[tiab] OR selfmanag*[tiab] OR “self care”[tiab] OR selfcar*[tiab]) OR (“motivational interviewing”[tiab] OR “motivational interview”[tiab] OR “motivational interviews”[tiab]) OR ((behavio*[tiab] OR exercis*[tiab] OR diet[tiab] OR fitness[tiab] OR “life style”[tiab] OR “life styles”[tiab] OR lifestyle*[tiab] OR nutrition[tiab] OR “physical activity”[tiab] OR “problem solving”[tiab] OR relax*[tiab]) AND (counsel*[tiab] OR intervention*[tiab] OR program*[tiab] OR therap*[tiab] OR train*[tiab] OR treat*[tiab])) OR (“directive counseling”[All Fields]) OR (“disease management”[All Fields]) OR (“community centre”[tiab] OR “community centres”[tiab] OR “community center”[tiab] OR “community centers”[tiab]) OR (“cognitive therapy”[tiab] OR “cognitive therapies”[tiab]) OR (“blood glucose monitoring”[tiab]) OR (“behavior therapy”[tiab] OR “behaviour therapy”[tiab] OR “behavior therapies”[tiab] OR “behaviour therapies”[tiab] OR “behavioral therapy”[tiab] OR “behavioural therapy”[tiab] OR “behavioral therapies”[tiab] OR “behavioural therapies”[tiab]) OR (“Weight Loss”[Mesh:noexp]) OR (“Self Care”[Mesh:noexp]) OR (“Self Medication”[Mesh]) OR (“Self Administration”[Mesh]) OR (“Relaxation Therapy”[Mesh:noexp]) OR (“Program Evaluation”[Mesh:noexp]) OR (“Patient Education as Topic”[Mesh:noexp]) OR (“Patient Compliance”[Mesh]) OR (“Patient Care Team”[Mesh]) OR (“Outcome Assessment (Health Care)”[Mesh:noexp]) OR (“Nutrition Therapy”[Mesh]) OR (“Health Promotion”[Mesh:noexp]) OR (“Health Education”[Mesh:noexp]) OR (“Health Behavior”[Mesh] AND (counsel* OR intervention* OR program* OR train*)) OR (“Directive Counseling”[Mesh]) OR (“Exercise Therapy”[Mesh]) OR (“Exercise”[Mesh] AND (counsel* OR intervention* OR program* OR train*)) OR (“Disease Management”[Mesh:noexp]) OR (“Community Health Centers”[Mesh:noexp]) OR (“Cognitive Therapy”[Mesh:noexp]) OR (“Blood Glucose Self-Monitoring”[Mesh]) OR (“Behavior Therapy”[Mesh:noexp]))) AND (((randomized controlled trial[pt]) OR (controlled clinical trial[pt]) OR (randomized[tiab]) OR (placebo[tiab]) OR (drug therapy[sh]) OR (randomly[tiab]) OR (trial[tiab]) OR (groups[tiab])) NOT (animals[mh] NOT humans[mh]))) OR (((((“Diabetes Mellitus”[Mesh]) OR (“Hypoglycemia”[Mesh]) OR (diabet*[tiab]) OR (“noninsulin dependent”[tiab] OR “non insulin dependent”[tiab] OR “insulin dependent”[tiab]) OR (T1DM[tiab] OR T2DM[tiab] OR IDDM[tiab] OR NIDDM[tiab])) NOT ((diabet*[tiab] AND (insipidus[tiab] NOT mellitus[tiab])) OR (“Diabetes Insipidus”[Mesh]))) AND ((“self manage”[tiab] OR “self managed”[tiab] OR selfmanag*[tiab] OR “self care”[tiab] OR selfcar*[tiab]) OR (“motivational interviewing”[tiab] OR “motivational interview”[tiab] OR “motivational interviews”[tiab]) OR ((behavio*[tiab] OR exercis*[tiab] OR diet[tiab] OR fitness[tiab] OR “life style”[tiab] OR “life styles”[tiab] OR lifestyle*[tiab] OR nutrition[tiab] OR “physical activity”[tiab] OR “problem solving”[tiab] OR relax*[tiab]) AND (counsel*[tiab] OR intervention*[tiab] OR program*[tiab] OR therap*[tiab] OR train*[tiab] OR treat*[tiab])) OR (“directive counseling”[All Fields]) OR (“disease management”[All Fields]) OR (“community centre”[tiab] OR “community centres”[tiab] OR “community center”[tiab] OR “community centers”[tiab]) OR (“cognitive therapy”[tiab] OR “cognitive therapies”[tiab]) OR (“blood glucose monitoring”[tiab]) OR (“behavior therapy”[tiab] OR “behaviour therapy”[tiab] OR “behavior therapies”[tiab] OR “behaviour therapies”[tiab] OR “behavioral therapy”[tiab] OR “behavioural therapy”[tiab] OR “behavioral therapies”[tiab] OR “behavioural therapies”[tiab]) OR (“Weight Loss”[Mesh:noexp]) OR (“Self Care”[Mesh:noexp]) OR (“Self Medication”[Mesh]) OR (“Self Administration”[Mesh]) OR (“Relaxation Therapy”[Mesh:noexp]) OR (“Program Evaluation”[Mesh:noexp]) OR (“Patient Education as Topic”[Mesh:noexp]) OR (“Patient Compliance”[Mesh]) OR (“Patient Care Team”[Mesh]) OR (“Outcome Assessment (Health Care)”[Mesh:noexp]) OR (“Nutrition Therapy”[Mesh]) OR (“Health Promotion”[Mesh:noexp]) OR (“Health Education”[Mesh:noexp]) OR (“Health Behavior”[Mesh] AND (counsel* OR intervention* OR program* OR train*)) OR (“Directive Counseling”[Mesh]) OR (“Exercise Therapy”[Mesh]) OR (“Exercise”[Mesh] AND (counsel* OR intervention* OR program* OR train*)) OR (“Disease Management”[Mesh:noexp]) OR (“Community Health Centers”[Mesh:noexp]) OR (“Cognitive Therapy”[Mesh:noexp]) OR (“Blood Glucose Self-Monitoring”[Mesh]) OR (“Behavior Therapy”[Mesh:noexp]))) AND (((“Cohort Studies”[Mesh:noexp]) OR (“Follow-Up Studies”[Mesh]) OR (“Longitudinal Studies”[Mesh:noexp]) OR (“Prospective Studies”[Mesh]) OR (“cohort analysis”[tiab] OR “cohort analyses”[tiab]) OR (“cohort study”[tiab] OR “cohort studies”[tiab]) OR (“controlled before and after”[tiab] OR “controlled before after”[tiab]) OR (control*[tiab] AND pre[tiab] AND post[tiab] AND (study[tiab] OR studies[tiab])) OR (“follow up study”[tiab] OR “follow up studies”[tiab]) OR (longitudinal[tiab]) OR (“observational study”[tiab] OR “observational studies”[tiab]) OR (prospective[tiab])) NOT (animals[mh] NOT humans[mh])))

## AADE Proceedings

Conference Proceeding: AADE Proceedings

Search Title: N/A

Date Searched: 27 June 2014

https://event.crowdcompass.com/aade14/custom-list/Schedule

URL provided by Michelle Crain, AADE Marketing and Communications Coordinator mcrain@aadenet.org

Note: No availability to abstracts from 2011-2013 meetings.

## ADA Proceedings

Conference Proceeding: ADA Proceedings (via Embase)

Search Title: N/A

Date Searched: 26 June 2014

Results: 3 PDFs

1. american diabetes association.ti.
2. limit 1 to (yr=2011 –Current” and (conference abstract or conference paper or conference proceeding or “conference review”)) (3)

## CDA Proceedings

Conference Proceeding: CDA Proceedings

Search Title: N/A

Date Searched: 27 June 2014

Results: 3 journal issues

Hand searched issues of the Canadian Journal of Diabetes on ScienceDirect:

http://www.sciencedirect.com/science/journal/14992671/

## EASD Proceedings

Conference Proceeding: EASD (European Association for the Study of Diabetes) Proceedings

Search Title: N/A

Date Searched: 27 June 20143

Results: 3 links

Meeting abstracts available through the EASD website:

http://www.easd.org/index.php?option=com_content&view=article&id=69&Itemid=509

## IDF Proceedings

Conference Proceeding[underlined: :] IDF Proceedings

Search Title: N/A

Date Searched: 27 June 2014

Results: 2 links (2012 conference not available)

Meeting abstracts available through the IDF website:

http://www.idf.org/final-programme

## SMB Proceedings

Conference Proceeding: SBM Proceedings

Search Title: N/A

Date Searched: 27 June 2014

Results: 4 links to program PDFs

Meeting abstracts/programs available through the SBM website:

http://www.sbm.org/meetings/past

## ISBNPA Proceedings

Conference Proceeding: ISBNPA (International Society for Behavioral, Nutrition and Physical Activity) Proceedings

Search Title: N/A

Date Searched: 27 June 2014

Results: 4 links to programs/abstracts

Meeting abstracts/programs available through the ISBNPA website:

https://secure.isbnpa.org/annual-meeting/index.cfm

## ClinicalTrials.gov

Trial Registry: ClinicalTrials.gov

Date Searched: 25 – 26 June, 2014

Results: 2070

1. “Diabetes Mellitus” [DISEASE] AND ( life style OR lifestyle OR life styles OR lifestyles ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (291)
2. “Diabetes Mellitus” [DISEASE] AND ( self management ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (197)
3. “Diabetes Mellitus” [DISEASE] AND ( behavior OR behaviour OR behavioral OR behavioural ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (710)
4. “Diabetes Mellitus” [DISEASE] AND ( education OR educational ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (403)
5. “Diabetes Mellitus” [DISEASE] AND ( blood glucose regulation ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (14)
6. “Diabetes Mellitus” [DISEASE] AND ( medication adherence ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (61)
7. “Diabetes Mellitus” [DISEASE] AND ((exercise OR physical activity) AND (diet OR dietary)) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (273)
8. “Diabetes Mellitus” [DISEASE] AND ( ( exercise OR physical activity ) AND ( relaxation OR biofeedback OR yoga OR meditation ) ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (10)
9. “Diabetes Mellitus” [DISEASE] AND ( ( diet OR dietary ) AND ( relaxation OR biofeedback OR yoga OR meditation ) ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (7)
10. “Diabetes Mellitus” [DISEASE] AND ( family ) [TREATMENT] AND ( “01/01/2009” : “12/31/2014” ) [FIRST-RECEIVED-DATE] (104)

## WHO ICTRP

Trial Registry: WHO ICTRP

Date Searched: 26 June 2014

Results: 422

Advance search interface: http://apps.who.int/trialsearch/AdvSearch.aspx

> “Condition” field: diabetes

> “Intervention” field: lifestyle OR self management OR behavior OR education OR family

> “Recruitment status” field is: ALL

> Date of registration is between: 01/01/2009 and 31/12/2014 (422)