# Abbreviations and Acronyms

95% CIs: 95 percent confidence intervals
AC: active control
AHRQ: Agency for Healthcare Research and Quality
BMI: body mass index
CDC: Centers for Disease Control and Prevention
DSME: diabetes self-management education
DSMP: Diabetes Self-Management Profile questionnaire
EOI: end of intervention
EPC: Evidence-based Practice Center
h: hour
HbA_1c_: hemoglobin A_1c_
HRQL: health-related quality of life
I^2^: I squared statistic (measure of statistical heterogeneity)
KIs: Key Informants
KQ: key question
m: month
MD: mean difference
n: number
NA: not applicable
NMA: network meta-analysis
NR: not reported
OR: odds ratio
PAID: Problem Areas in Diabetes questionnaire
PB: “probability of being best”
PICOTS: populations, interventions, comparators, outcomes, timing, settings
QOL: quality of life
RCT: randomized controlled trial
ROB: risk of bias
RR: risk ratios
SD: standard deviation
SDSCA: Summary of Diabetes Self-Care Activities
SMBG: self-monitoring of blood glucose
SMD: standardized mean differences
SOE: strength of evidence
SRDR: Systematic Review Data Repository
T1DM: type 1 diabetes mellitus
T2DM: type 2 diabetes mellitus
TEP: Technical Expert Panel
TOO: Task Order Officer
U.S.: United States
UC: usual care
UK: United Kingdom
VO_2_max: maximal oxygen uptake
yr: year