# Evidence Tables

Evidence Table 1. Description of 12 unused randomized controlled trials

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
A randomized comparison of sequential-gradient calf compression with intermittent plantar compression for prevention of venous thrombosis in orthopedic trauma patients: preliminary results. | Anglen, Bagby, and George, 1998 | Randomized controlled trial Quality Score 2 | Duplex of the injured side on days 2, 7, and 14 after surgery. Prophylaxis by SCD or AVF. | Patients randomized to either SCD or foot pumps. 124 patients included; 117 eventually analyzed. Randomization by medical record number. | DVT developed in 3 (2.5%) patients. All 3 among 68 in the foot pump group (4.4%). None among 49 in the SCD group (p=NS). No adverse events were observed. There was 1 PE in the foot pump group.
Low molecular weight heparin for the prevention of thromboembolism in outpatients immobilized by plaster cast. | Spannagel and Kujath, 1993 | Randomized controlled trial Quality Score 0 | Duplex upon removal of cast. Venography for positive tests. Prophylaxis by LMWH or placebo. | 306 patients included, 253 analyzed; 127 randomized to receive no prophylaxis and 126 to receive LMWH (36 mg CY 216). | DVT developed in 27 (10.6%) patients, 24 distal and 3 proximal. 21 patients belonged to the no-prophylaxis group and 6 (4.7%) received LMWH (p<0.01). Risk factors for DVT were age >30, obesity, varicose veins, and fractures.
Thromboembolic prophylaxis in orthopaedic trauma patients: a comparison between a fixed dose and an individually adjusted dose of a low molecular weight heparin (nadroparin calcium). | Haentjens, 1996 | Randomized controlled trial Quality Score 2 | Duplex on day 10 and week 6 or as clinically indicated. Positive test confirmed by venography. Prophylaxis by LMWH. | 285 randomized to fixed dose or a weight-adjusted dose of LMWH (nadroparin). 215 analyzed up to 10 days and 150 up to 6 weeks. | DVT developed in 1 fixed-dose patient and 4 adjusted-weight dose. 5 bleedings and 1 thrombocytopenia occurred in each group.
Use of low molecular weight heparin in preventing thromboembolism in trauma patients. | Knudson, Morabito, Paiement, et al., 1996 | Randomized controlled trial Quality Score 3 | Duplex on admission and every 5-7 days. Prophylaxis by LMWH,LDH, SCD, AVF, or LDH. | 487 patients included, 372 analyzed. 202 were stratified to the heparin group and were randomized to receive LMWH (120) or optimal compression (82) by SCD (61) or foot pumps (21). 170 were stratified to the no-heparin group and received optimal compression. | DVT developed in 9 (2.4%) patients and PE (nonfatal) in 1. In randomized patients DVT developed in 1 LMWH and 2 compression. 6 more nonrandomized patients of the no-heparin group had DVT.
Implementing ambulatory prevention of thrombosis with low molecular weight heparin in plaster immobilization of the lower extremity. | Kock, Schmit-Neuerburg, Hanke, et al., 1994 | Randomized controlled trial Quality Score 2 | IP and U/S before placement and after removal of the cast. Venography for positive tests. Prophylaxis by LMWH or nothing. | 176 patients randomized to self-administered LMWH (Embolex) and 163 to no prophylaxis. | DVT in no-LMWH patients and 7 (4.2%) no-prophylaxis patients.
Prevention of thromboembolism with heparin and dihydroergotamine in a trauma surgery patient sample--comparison of the effectiveness of different administration forms of dihydroergotamine. | Schott, Elsel, Mockel, et al., 1992 | Randomized controlled trial Quality Score 1 | 125 I-fibrinogen daily for first week. If positive >3 days, phlebography. LDH and DHE in all patients. | 60 patients randomized to LDH 5,000 SC 12 h and DHE 1 mg 8 h (30 patients) or LDH and DHE 0.5 mg 12 h (30 patients). | 1 DVT developed in the second group.
Fixed- vs adjusted-dose heparin in the prophylaxis of thromboembolism in spinal-cord injury. | Green, Lee, Ito, et al., 1988 | Randomized controlled trial Quality Score 4 | Duplex and impedance plethysomography every 3 days for 2 weeks and once weekly for 10 weeks. Positive results confirmed by venography. Prophylaxis by LDH. | Patients randomized to fixed LDH (5,000 SC 12 h) or adjusted-dose LDH (to prolong APTT to 1.5 times control). 75 randomized and 58 analyzed. | VT developed in 9 of 29 (31%) with fixed LDH (2 proximal DVT, 4 distal DVT, 3 PE) and 2 (1 proximal and 1 distal DVT) of 29 (7%) with adjusted LDH (p<0.05). More patients bled in the adjusted LDH group (7 vs. none, p<0.02).
Prevention of venous thromboses under plaster casts after leg injury. Comparison of heparin-calcium and pentosan sulfuric polyester. | Normand and Mathieu, 1987 | Randomized controlled trial Quality Score 1 | Only casted patients. Patients were assigned a risk score according to a list of risk factors. Polysulfate of pentosane vs. calcium heparin. Diagnosis based on clinical examination. | 60 patients included (30 in each group). | 3 DVTs in the PSP group, 1 DVT in the HC group.
An evaluation of suloctidil in the prevention of deep vein thrombosis in neurosurgical patients. | Turpie, Gent, Doyle, et al., 1985 | Randomized controlled trial Quality Score 4 | 125 I-fibrinogen scanning daily for up to 14 days folowing surgery; impedance plethysmography every second day. | 39 patients randomized to 200 mg suloctidil (an antiplatelet agent) or placebo. | DVT developed in 10 (25%) patients. There were 4 of 19 (21%) randomized to suloctidil and 6 of 20 (30%) to placebo (p=NS).
Deep vein thrombosis in spinal-cord injury: effect of prophylaxis with calf compression, aspirin, and dipyridamole. | Green, Rossi, Yao, et al., 1982 | Randomized controlled trial Quality Score 2 | Daily 125 I-fibrinogen test. Impedance plethysmography on admission and every 72 hours thereafter. Prophylaxis by SCD or SCD and aspirin. | 28 patients included, 27 analyzed. 15 randomized to SCD alone and 12 to SCD with aspirin and dypiridamole. | DVT developed in 6 of SCD patients and 3 of SCD/aspirin/dypiridamole patients (0.4% vs. 0.25%, p=NS). There were 3 proximal DVTs in the former group and 1 in the latter. 1 patient receiving SCD/aspirin/dypiridamole bled.
A comparison of acetylsalicylic acid with low-molecular-weight heparin for prophylaxis of deep-vein thrombosis in outpatients with injuries and immobilizing bandages of the lower limb. | Gehling, Giannadakis, Lefering, et al., 1998 | Randomized controlled trial Quality Score 2 | U/S upon removal of cast. Venography for positive U/S. Prophylaxis by aspirin or LMWH. | 144 patients randomized to receive aspirin 500 mg po 12 h and 143 to LMWH (Clivarin) 0.85 mg SC daily. | DVT developed in 7 (4.8%) aspirin patients and 9 (6.2%) LMWH patients, proximal DVT in 1 and 2 patients, respectively. Only minor complications.
Prophylaxis for deep vein thrombosis in acute spinal-cord injury comparing two doses of low molecular weight heparinoid in combination with external pneumatic compression. | Merli, Doyle, Crabbe, et al., 1991 | Randomized controlled trial Quality Score 2 | Daily surveillance with 125 I-fibrinogen scanning and Duplex on day 14. Venography on all with positive above tests. Prophylaxis by low-molecular-weight heparinoid (Organan). | 42 evaluable patients randomized to either ORG 10172, 750 units SC daily (Group A) or ORG 10172, 1,250 units SC (Group B) daily. All patients had pneumatic compression. | DVT developed in 3 Group A (18%) vs. 2 Group B (7%) patients.

Evidence Table 2. Four randomized controlled trials comparing low-dose heparin vs. no prophylaxis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Prevention of venous thromboembolism in trauma patients. | ^1^ Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, or pelvic or lower extremity fractures.
Deep vein thrombosis: prophylaxis in acute spinal-cord injured patients. | Merli, Herbison, Ditunno, et al., 1988 | Randomized controlled trial Quality Score 4 | 125 I-fibrinogen scan plus IPG on admission. If either (+), venography. Prophylaxis by LDH or nothing. | 53 included, 48 patients analyzed: 17 placebo, 16 LDH 5,000, 15 LDH, and electric stimulation. | DVT developed in 8 placebo (47%), 8 LDH (50%), and 1 LDH + electric stimulation (6.7%).
Low dose heparin prophylaxis for deep venous thrombosis in acute spinal-cord injury patients: a controlled study. | Frisbie and Sasahara, 1981 | Randomized controlled trial Quality Score 0 | Impedance plethysmography weekly and venography for positive studies. Prophylaxis by LDH or nothing. | 32 patients included. 15 were randomized to LDH 5,000 SC 12 h, and 17 to no heparin. | 1 LDH patient (6.6%) and 1 no heparin patient (5.8%) developed DVT.

1 Two RCTs were used from the Knudson study.

Evidence Table 3. Three randomized controlled trials comparing mechanical prophylaxis vs. no prophylaxis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Prevention of venous thromboembolism in trauma patients. | ^1^ Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, or pelvic or lower extremity fractures.
Effectiveness of pneumatic leg compression devices for the prevention of thromboembolic disease in orthopaedic trauma patients: a prospective, randomized study of compression alone versus no prophylaxis. | Fisher, Blachut, Salvian, et al., 1995 | Randomized controlled trial Quality Score 3 | Doppler on admission and every 5 days. Duplex on day 3-5, V/Q scan on day 5-10. Prophylaxis by SCD or nothing. | 73 patients with pelvic fractures randomized to either SCD (35) or no prophylaxis (38). | DVT developed in 1 with SCD and 3 without SCD. PE developed in 2 with SCD and 1 without SCD.

1 Two RCTs were used from the Knudson study.

Evidence Table 4. Three studies comparing low-dose heparin vs. low-molecular-weight heparin

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Fatal pulmonary embolism in spinal-cord injury. | Green, Twardowski, Wei, et al., 1994 | Single cohort Quality Score ^1^ | Diagnosis by autopsy. Prophylaxis by LDH or LMWH. | 51 patients included. Prophylaxis with unfractionated heparin in 22, LMWH in 27 (2 did not receive heparin). | 9 (16.7%) developed PE. Of 22 patients treated with unfractionated heparin 7 (31.8%) developed PE. Of patients treated with LMWH, 2 (7%) developed PE.
A comparison of low-dose heparinwith low-molecular-weight heparin as prophylaxis against venous thromboembolism after major trauma. | Geerts, Jay, Code, et al., 1996 | Randomized controlled trial Quality Score 5 | Venography 10-14 days after admission. Also, ultrasonography when indicated. Prophylaxis by LDH or LMWH. | 265 patients included. 136 randomized to LDH (5,000 units/12 h) and 129 to LMWH (30 mg/12 h). | DVT in 60 LDH and 40 LMWH (44% vs. 31%, p=0.014). Proximal DVT in 15% vs. 6% respectively (p=0.012). Major bleeding in 1 LDH vs. 5 LMWH (p=0.12).
Prevention of thromboembolismafter spinal-cord injury using low-molecular-weight heparin. | Green, Lee, Lim, et al., 1990 | Randomized controlled trial Quality Score 2 | IP and Duplex on admission, twice weekly for 2 weeks, once weekly for 2 more, and biweekly for 4 more. Prophylaxis by LDH or LMWH. | 41 patients included; 21 randomized to LDH 5,000 SC 8 h and 20 randomized to LMWH (logiparin). | Thrombotic or bleeding events developed in 7 (33%) of LDH patients and none of LMWH patients (p= 0.006); DVT in 3 vs. O, PE in 2 vs. O, and bleeding in 2 vs. 0.

Evidence Table 5. Four studies comparing low-dose heparin vs. mechanical prophylaxis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
The role of ultrasonography and inferior vena cava filter placement in high-risk trauma patients. | Headrick, Barker, Pate, et al., 1997 | Prospective cohorts with retrospective control cohort Quality Score 5 | U/S within 72 hours of admission and every week after that, until discharge. Prophylaxis by LDH 5,000 SC 12-hourly and/or SCD. | 228 patients included prospectively. They were compared with 234 historical controls with the same inclusion criteria. If U/S positive, patients anticoagulated and considered for VCF (for proximal DVT). | DVT developed in 37 (17%). Independent risk factors for DVT were age and lower extremity trauma. Of 26 DVT patients who received VCF, none suffered PE. Of 10 DVT patients without VCF, 1 had fatal PE.
Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. | Dennis, Menawat, Von Thron, et al., 1993 | Prospective comparative cohorts Quality Score 6 | Duplex within 48 hours of admission and every 5 daysthereafter. Prophylaxis by SCD or LDH or nothing. | 395 patients included. 281 randomized to receive VT prophylaxis and 114 to no prophylaxis. | DVT developed in 8 patients with prophylaxis and 10 without (2.9 vs. 8.8%, p<0.02). 2 PE in each group. Risk factor of DVT was spinal trauma.
Thromboembolism following multiple trauma. | Knudson, Collins, Goodman, et al., 1992 | Randomized controlled trial Quality Score 1 | Duplex within 24 hours of admission and every 5 days up to 3 weeks or discharge. Prophylaxis by SCD or LDH. | 113 patients included. 76 randomized to SCD and 37 to LDH 5,000 12 h (11 patients with contraindications to LDH were assigned to the SCD group). | VT developed in 12 patients (5 DVT, 4 PE, 3 both); 9 in the SCD group and 3 in the LDH group. Risk factors for VT were age, immobilization, number of transfusions, and clotting abnormalities.
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.

Evidence Table 6. Five studies comparing mechanical prophylaxis vs. no prophylaxis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
The role of ultrasonography and inferior vena cava filter placement in high-risk trauma patients. | Headrick, Barker, Pate, et al., 1997 | Prospective cohorts with retrospective control cohort Quality Score 5 | U/S within 72 hours of admission and every week after that, until discharge. Prophylaxis by LDH 5,000 SC 12-hourly and/or SCD. | 228 patients included prospectively. They were compared with 234 historical controls with the same inclusion criteria. If U/S positive, patients anticoagulated and considered for VCF (for proximal DVT). | DVT developed in 37 (17%). Independent risk factors for DVT were age and lower extremity trauma. Of 26 DVT patients who received VCF, none suffered PE. Of 10 DVT patients without VCF, 1 had fatal PE.
Prevention of venous thromboembolism in trauma patients. | ^1^ Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. | Dennis, Menawat, Von Thron, et al., 1993 | Prospective comparative cohorts Quality Score 6 | Duplex within 48 hours of admission and every 5 days thereafter. Prophylaxis by SCD or LDH or nothing. | 395 patients included. 281 randomized to receive VT prophylaxis and 114 to no prophylaxis. | DVT developed in 8 patients with prophylaxis and 10 without (2.9 vs. 8.8%, p<0.02). 2 PE in each group. Risk factor of DVT was spinal trauma.
Effectiveness of pneumatic leg compression devices for the prevention of thromboembolic disease in orthopaedic trauma patients: A prospective, randomized study of compression alone versus no prophylaxis. | Fisher, Blachut, Salvian, et al., 1995 | Randomized controlled trial Quality Score 3 | Doppler on admission and every 5 days. Duplex on day 3-5, V/Q scan on day 5-10. Prophylaxis by SCD or nothing. | 73 patients with pelvic fractures randomized to either SCD (35) or no prophylaxis (38). | DVT developed in 1 with SCD and 3 without SCD. PE developed in 2 with SCD and 1 without SCD.

1 Two RCTs were used from the Knudson study.

Evidence Table 7. Six studies comparing low-dose heparin vs. no prophylaxis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
The role of ultrasonography and inferior vena cava filter placement in high-risk trauma patients. | Headrick, Barker, Pate, et al., 1997 | Prospective cohorts with retrospective control cohort Quality Score 5 | U/S within 72 hours of admission and every week after that, until discharge. Prophylaxis by LDH 5,000 SC 12 h and/or SCD. | 228 patients included prospectively. They were compared with 234 historical controls with the same inclusion criteria. If U/S positive, patients anticoagulated and considered for VCF (for proximal DVT). | DVT developed in 37 (17%). Independent risk factors for DVT were age and lower extremity trauma. Of 26 DVT patients who received VCF, none suffered PE. Of 10 DVT patients without VCF, 1 had fatal PE.
Prevention of venous thromboembolism in trauma patients. | ^1^ Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD, or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. | Dennis, Menawat, Von Thron, et al., 1993 | Prospective comparative cohorts Quality Score 6 | Duplex within 48 hours of admission and every 5 days thereafter. Prophylaxis by SCD or LDH or nothing. | 395 patients included. 281 randomized to receive VT prophylaxis and 114 to no prophylaxis. | DVT developed in 8 patients with prophylaxis and 10 without (2.9 vs. 8.8%, p<0.02). 2 PE in each group. Risk factor of DVT was spinal trauma.
Heparin, deep venous thrombosis, and trauma patients. | Ruiz, Hill, and Berry, 1991 | Prospective comparative cohorts Quality Score 5 | Duplex on days 1, 3, 6, 10, 21, or until discharged. Prophylaxis by LDH or nothing. | 100 patients included. At the discretion of the physician, 50 received no prophylaxis and 50 received LDH (5,000 SC 12 h). | DVT developed in 15 patients (15%). There were 14 (28%) in the LDH group and 1 (2%) in the no-heparin group (p<0.0001). The heparin group had higher ISS, lower GCS, more extremity injuries, and longer immobilization.
Deep vein thrombosis: Prophylaxis in acute spinal cord injured patients. | Merli, Herbison, Ditunno, et al., 1988 | Randomized controlled trial Quality Score 4 | 125 I-fibrinogen scan plus IPG on admission. If either (+), venography. Prophylaxis by LDH or nothing. | 53 included, 48 patients analyzed: 17 placebo, 16 LDH 5,000, 15 LDH and electric stimulation. | DVT developed in 8 placebo (47%), 8 LDH (50%), and 1 LDH+electric stimulation (6.7%).
Low dose heparin prophylaxis for deep venous thrombosis in acute spinal-cord injury patients: A controlled study. | Frisbie and Sasahara, 1981 | Randomized controlled trial Quality Score 0 | Impedance plethysmography weekly and venography for positive studies. Prophylaxis by LDH or nothing. | 32 patients included. 15 were randomized to LDH 5,000 SC 12 h and 17 to no heparin. | 1 LDH patient (6.6%) and 1 no-heparin patient (5.8%) developed DVT.

1 Two RCTs were used from the Knudson study.

Evidence Table 8. Four studies using gender as a risk factor

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/ 12 h or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Low molecular weight heparin for the prevention of thromboembolism in outpatients immobilized by plaster cast. | Spannagel and Kujath, 1993 | Randomized controlled trial Quality Score 0 | Duplex upon removal of cast. Venography for positive tests. Prophylaxis by LMWH or placebo. | 306 patients included, 253 analyzed; 127 randomized to receive no prophylaxis and 126 to LMWH (36 mg CY 216). | DVT developed in 27 (10.6%) patients, 24 distal and 3 proximal. 21 patients belonged to the no-prophylaxis group and 6 (4.7%) received LMWH (p<0.01). Risk factors for DVT were age >30, obesity, varicose veins, and fractures.
Incidence of deep-vein thrombosis in patients with fractures of the lower extremity distal to the hip. | Abelseth, Buckley, Pineo, et al., 1996 | Single cohort Quality Score 4 | Venogram after operative fixation (day 3-22) as outpatient. No prophylaxis. | 102 patients included. | DVT developed in 29 (28%) patients and PE in 2. Risk factors for DVT were age >60, OR time >105 miniutes, time from injury to operation >27 h.
Acute spinal cord injuries and the incidence of clinically occurring thromboembolic disease. | Waring, Karunas, and Paraplegia, 1991 | Single Cohort Quality Score 1 | Prophylaxis or screening methods not described. | 1,419 patients included. Stratification according to age, gender, level of injury, and type of injury. | DVT developed in 14.5% and PE in 4.6%. Age was the only significant risk factor for PE.

Evidence Table 9. Eight studies using head injury as a risk factor

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. | Dennis, Menawat, Von Thron, et al., 1993 | Prospective comparative cohorts Quality Score 6 | Duplex within 48 hours of admission and every 5 days thereafter. Prophylaxis by SCD, LDH, or nothing. | 395 patients included. 281 randomized to receive VT prophylaxis and 114 to no prophylaxis. | DVT developed in 8 patients with prophylaxis and 10 without (2.9 vs. 8.8%, p<0.02). 2 PE in each group. Risk factor of DVT was spinal trauma.
Surveillance venous scans for deep venous thrombosis in multiple trauma patients. | Meyer, Blebea, Davis, et al., 1995 | Single cohort Quality Score 1 | Duplex scans at no specific times. All patients had either LDH 5,000 SC 12 h or SCD. | 183 patients included. | DVT developed in 22 (12%) patients (16 proximal, 6 distal). Patients with symptoms of DVT or with spinal injuries more likely to develop DVT.
Thromboembolism following multiple trauma. | Knudson, Collins, Goodman, et al., 1992 | Randomized controlled trial Quality Score 1 | Duplex within 24 hours of admission and every 5 days up to 3 weeks or discharge. Prophylaxis by SCD or LDH. | 113 patients included. 76 randomized to SCD and 37 to LDH 5,000 12 h (11 patients with contraindications to LDH were assigned to the SCD group). | VT developed in 12 patients (5 DVT, 4 PE, 3 both); 9 in the SCD group and 3 in the LDH group. Risk factors for VT were age, immobilization, number of transfusions, and clotting abnormalities.
Venous thromboembolism in the high-risk trauma patient: Do risks justify aggressive screening and prophylaxis? | Spain, Richardson, Polk, et al., 1997 | Single cohort Quality Score 1 | Only based on clinical suspicion. Prophylaxis varied. | 280 patients with high-risk criteria included; compared with 2,249 low-risk patients. | DVT at high risk in 12 patients (5%) and low risk in 3 (0.1%, p<0.05). PE in 4 (1.4%) vs. none (p<0.05).
Is deep vein thrombosis surveillance warranted in high-risk trauma patients? | Piotrowski, Alexander, Brandt, et al., 1996 | Single cohort Quality Score 3 | Duplex scan within 48 hours of admission, weekly for 3 weeks, biweekly for 3 weeks, monthly until discharge. Prophylaxis with LDH (46.6%), thromboembolic stockings (74%) or SCD (81.3%). 3.8% no prophylaxis. | 343 patients included. | 20 patients developed DVT (5.8%) and 3 PE (1%). Multivariate analysis revealed age and GCS as independent risk factors for DVT. The cost of the screening program was $18,000 per DVT or 5% of total bed charges.
Silent deep vein thrombosis in immobilized multiple trauma patients. | Kudsk, Fabian, Baum, et al., 1989 | Single cohort Quality Score 2 | Venography between days 7-12 after injury. No prophylaxis used. | 39 patients included. | 24 patients developed DVT, 12 proximal DVT. Risk factor for DVT was age.
Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient? | Velmahos, Nigro, Tatevossian, et al., 1998 | Single cohort Quality Score 5 | Duplex scan of proximal legs (popliteal fossa to inguinal ligament) and iliac veins whenever possible. Prophylaxis by LDH, SCD, or both. | 200 patients included. 197 had DVT prophylaxis: 92 (46%) LDH, 195 (97.5%) SCD, 90 (45%) both. | Proximal DVT developed in 26 (13%) patients. Patients with DVT had more severe chest and extremity injuries and required higher levels of PEEP during mechanical support. Combined use of LDH and SCD did not decrease DVT rate any further. 4 (2%) had PE.

Evidence Table 10. Twelve studies using long-bone fracture as a risk factor

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Deep venous thrombosis in the trauma patient. | Hill, Berry, and Ruiz, 1994 | Prospective comparative cohorts Quality Score 5 | Duplex scans on days 1, 3, 6, 10, 21 or until discharge. Prophylaxis by LDH or nothing. | 100 patients studied. 50 received LDH and 50 did not at the discretion of the surgeon. | 15 patients developed DVT. Only 1 was not receiving prophylaxis. There were more lower extremity injuries and a higher ISS in patients with DVT vs. those without DVT.
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Asymptomatic deep venous thrombosis in the trauma patient: Is an aggressive screening protocol justified? | Napolitano, Garlapati, Heard, et al., 1995 | Single cohort Quality Score 2 | Duplex twice weekly. DVT prophylaxis by either LDH or SCD or both according to physician's preference. | 458 patients included. | DVT developed in 45 (10%). 1 PE was found. Multivariate analysis identified age, ISS, RTS, length of stay, and spinal injury to be independently associated with DVT.
Use of low molecular weight heparin in preventing thromboembolism in trauma patients. | ^1^ Knudson, Morabito, Paiement, et al., 1996 | Randomized controlled trial Quality Score 3 | Duplex on admission and every 5-7 days. Prophylaxis by LMWH, LDH, SCD, AVF, or LDH. | 487 patients included, 372 analyzed. 202 were stratified to the heparin group and were randomized to receive LMWH (120) or optimal compression (82) by SCD (61) or foot pumps (21). 170 were stratified to the no-heparin group and received optimal compression. | DVT developed in 9 (2.4%) patients and PE (nonfatal) in 1. In randomized patients, DVT developed in 1 LMWH and 2 compression. 6 more nonrandomized patients of the no-heparin group had DVT.
Incidence of deep-vein thrombosis in patients with fractures of the lower extremity distal to the hip. | Abelseth, Buckley, Pineo, et al., 1996 | Single cohort Quality Score 4 | Venogram after operative fixation (day 3-22) as outpatient. No prophylaxis. | 102 patients included. | DVT developed in 29 (28%) patients and PE in 2. Risk factors for DVT were age >60, operating room time >105 miniutes, time from injury to operation >27 h.
A comparison of low-dose heparin with low-molecular-weight heparin as prophylaxis against venous thromboembolism after major trauma. | Geerts, Jay, Code, et al., 1996 | Randomized controlled trial Quality Score 5 | Venography 10-14 days after admission. Also, ultrasonography when indicated. Prophylaxis by LDH or LMWH. | 265 patients included. 136 randomized to LDH (5,000 units/12 h) and 129 to LMWH (30 mg/12 h). | DVT in 60 LDH and 40 LMWH (44% vs. 31%, p=0.014). Proximal DVT in 15% vs. 6%, respectively (p=0.012). Major bleeding in 1 LDH vs. 5 LMWH (p=0.12).
A prospective study of venous thromboembolism after major trauma. | Geerts, Code, Jay, et al., 1994 | Single cohort Quality Score 5 | Bilateral contrast venography 14-21 days after admission and impedance plethysmography every other day. No prophylaxis used during study. | 349 patients with adequate venographic studies. Venography was unsuccesful due to failure of venous access in 12.6% and was inconclusive in 8.6% of patients in whom it was attempted. | 201 (57.6%) had DVT and 63 (18.1%) proximal DVT. Confirmed PE. developed in 7 (2%). Multiple logistic regression identified the following independent factors associated with DVT: age (OR: 1.05 per year), blood transfusion (1.74), surgery (2.30), fracture of femur or tibia (4.82), and spinal-cord injury (8.59).
Thromboembolism following multiple trauma. | Knudson, Collins, Goodman, et al., 1992 | Randomized controlled trial Quality Score 1 | Duplex within 24 hours of admission and every 5 days up to 3 weeks or discharge. Prophylaxis by SCD or LDH. | 113 patients included. 76 randomized to SCD and 37 to LDH 5,000 units/12 h (11 patients with contraindications to LDH were assigned to the SCD group). | VT developed in 12 patients (5 DVT, 4 PE, 3 both); 9 in the SCD group and 3 in the LDH group. Risk factors for VT were age, immobilization, number of transfusions, and clotting abnormalities.
Venous thromboembolism in the high-risk trauma patient: Do risks justify aggressive screening and prophylaxis? | Spain, Richardson, Polk, et al., 1997 | Single cohort Quality Score 1 | Only based on clinical suspicion. Prophylaxis varied. | 280 patients with high-risk criteria included; compared with 2,249 low-risk patients. | DVT at high risk in 12 patients (5%) and low risk in 3 (0.1%, p<0.05). PE in 4 (1.4%) vs. none (p<0.05).
Is deep vein thrombosis surveillance warranted in high-risk trauma patients? | Piotrowski, Alexander, Brandt, et al., 1996 | Single cohort Quality Score 3 | Duplex scan within 48 hours of admission, weekly for 3 weeks, biweekly for 3 weeks, monthly until discharge. Prophylaxis with LDH (46.6%), thromboembolic stockings (74%) or SCD (81.3%). 3.8% no prophylaxis. | 343 patients included. | 20 patients developed DVT (5.8%) and 3 PE (1%). Multivariate analysis revealed age and GCS as independent risk factors for DVT. The cost of the screening program was $18,000 per DVT or 5% of total bed charges.
Silent deep vein thrombosis in immobilized multiple trauma patients. | Kudsk, Fabian, Baum, et al., 1989 | Single cohort Quality Score 2 | Venography between days 7 and 12 after injury. No prophylaxis used. | 39 patients included. | 24 patients developed DVT, 12 proximal DVT. Risk factor for DVT was age.
Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient? | Velmahos, Nigro, Tatevossian, et al., 1998 | Single cohort Quality Score 5 | Duplex scan of proximal legs (popliteal fossa to inguinal ligament) and iliac veins whenever possible. Prophylaxis by LDH, SCD, or both. | 200 patients included. 197 had DVT prophylaxis: 92 (46%) LDH, 195 (97.5%) SCD, 90 (45%) both. | Proximal DVT developed in 26 (13%) patients. Patients with DVT had more severe chest and extremity injuries and required higher levels of PEEP during mechanical support. Combined use of LDH and SCD did not decrease DVT rate any further. 4 (2%) had PE.

Evidence Table 11. Eight studies using pelvic fracture as a risk factor

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or power extremity fractures.
Asymptomatic deep venous thrombosis in the trauma patient: Is an aggressive screening protocol justified? | Napolitano, Garlapati, Heard, et al., 1995 | Single cohort Quality Score 2 | Duplex twice weekly. DVT prophylaxis by either LDH or SCD or both according to physician's preference. | 458 patients included. | DVT developed in 45 (10%). 1 PE was found. Multivariate analysis identified age, ISS, RTS, length of stay, and spinal injury to be independently associated with DVT.
Use of low molecular weight heparin in preventing thromboembolism in trauma patients. | ^1^ Knudson, Morabito, Paiement, et al., 1996 | Randomized controlled trial Quality Score 3 | Duplex on admission and every 5-7 days. Prophylaxis by LMWH, SCD, AVF, or LDH. | 487 patients included, 372 analyzed. 202 were stratified to the heparin group and were randomized to receive LMWH (120) or optimal compression (82) by SCD (61) or foot pumps (21). 170 were stratified to the no-heparin group and received optimal compression. | DVT developed in 9 (2.4%) patients and PE (nonfatal) in 1. In randomized patients, DVT developed in 1 LMWH and 2 compression. 6 more nonrandomized patients of the no-heparin group had DVT.
A prospective study of venous thromboembolism after major trauma. | Geerts, Code, Jay, et al., 1994 | Single cohort Quality Score 5 | Bilateral contrast venography 14-21 days after admission and impedance plethysmography every other day. No prophylaxis used during study. | 349 patients with adequate venographic studies. Venography was unsuccesful due to failure of venous access in 12.6% and was inconclusive in 8.6% of patients in whom it was attempted. | 201 (57.6%) had DVT and 63 (18.1%) proximal DVT. Confirmed PE developed in 7 (2%). Multiple logistic regression identified the following independent factors associated with DVT: age (OR: 1.05 per year), blood transfusion (1.74), surgery (2.30), fracture of femur or tibia (4.82), and spinal cord injury (8.59).
Venous thromboembolism in the high-risk trauma patient: Do risks justify aggressive screening and prophylaxis? | Spain, Richardson, Polk, et al., 1997 | Single cohort Quality Score 1 | Only based on clinical suspicion. Prophylaxis varied. | 280 patients with high-risk criteria included; compared with 2,249 low-risk patients. | DVT at high risk in 12 patients (5%) and low risk in 3 (0.1%, p<0.05). PE in 4 (1.4%) vs. none (p<0.05).
Is deep vein thrombosis surveillance warranted in high-risk trauma patients? | Piotrowski, Alexander, Brandt, et al., 1996 | Single cohort Quality Score 3 | Duplex scan within 48 hours of admission, weekly for 3 weeks, biweekly for 3 weeks, monthly until discharge. Prophylaxis with LDH (46.6%), thromboembolic stockings (74%), or SCD (81.3%). 3.8% no prophylaxis. | 343 patients included. | 20 patients developed DVT (5.8%) and 3 PE (1%). Multivariate analysis revealed age and GCS as independent risk factors for DVT. The cost of the screening program was $18,000 per DVT or 5% of total bed charges.
Silent deep vein thrombosis in immobilized multiple trauma patients. | Kudsk, Fabian, Baum, et al., 1989 | Single cohort Quality Score 2 | Venography between days 7 and 12 after injury. No prophylaxis used. | 39 patients included. | 24 patients developed DVT, 12 proximal DVT. Risk factor for DVT was age.
Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient? | Velmahos, Nigro, Tatevossian, et al., 1998 | Single cohort Quality Score 5 | Duplex scan of proximal legs (popliteal fossa to inguinal ligament) and iliac veins whenever possible. Prophylaxis by LDH, SCD, or both. | 200 patients included. 197 had DVT prophylaxis: 92 (46%) LDH, 195 (97.5%) SCD, 90 (45%) both. | Proximal DVT developed in 26 (13%) patients. Patients with DVT had more severe chest and extremity injuries and required higher levels of PEEP during mechanical support. Combined use of LDH and SCD did not decrease DVT rate any further. 4 (2%) had PE.

Evidence Table 12. Ten studies using spinal fracture as a risk factor

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. | Dennis, Menawat, Von Thron, et al., 1993 | Prospective comparative cohorts Quality Score 6 | Duplex within 48 hours of admission and every 5 days thereafter. Prophylaxis by SCD or LDH or nothing. | 395 patients included. 281 randomized to receive VT prophylaxis and 114 to no prophylaxis. | DVT developed in 8 patients with prophylaxis and 10 without (2.9 vs. 8.8%, p<0.02). 2 PE in each group. Risk factor of DVT was spinal trauma.
Asymptomatic deep venous thrombosis in the trauma patient: Is an aggressive screening protocol justified? | Napolitano, Garlapati, Heard, et al., 1995 | Single cohort Quality Score 2 | Duplex twice weekly. DVT prophylaxis by either LDH or SCD or both according to physician's preference. | 458 patients included. | DVT developed in 45 (10%). 1 PE was found. Multivariate analysis identified age, ISS, RTS, length of stay, and spinal injury to be independently associated with DVT.
Use of low molecular weight heparin in preventing thromboembolism in trauma patients. | Knudson, Morabito, Paiement, et al., 1996 | Randomized controlled trial Quality Score 3 | Duplex on admission and every 5-7 days. Prophylaxis by LMWH, SCD, AVF, or LDH. | 487 patients included, 372 analyzed. 202 were stratified to the heparin group and were randomized to receive LMWH (120) or optimal compression (82) by SCD (61) or foot pumps (21). 170 were stratified to the no-heparin group and received optimal compression. | DVT developed in 9 (2.4%) patients and PE (nonfatal) in 1. In randomized patients, DVT developed in 1 LMWH and 2 compression. 6 more nonrandomized patients of the no-heparin group had DVT.
Surveillance venous scans for deep venous thrombosis in multiple trauma patients. | Meyer, Blebea, Davis, et al., 1995 | Single cohort Quality Score 1 | Duplex scans at no specific times. All patients had either LDH 5,000 SC 12 h or SCD. | 183 patients included. | DVT developed in 22 (12%) patients (16 proximal, 6 distal). Patients with symptoms of DVT or with spinal injuries more likely to develop DVT.
A prospective study of venous thromboembolism after major trauma. | Geerts, Code, Jay, et al., 1994 | Single cohort Quality Score 5 | Bilateral contrast venography 14-21 days after admission and impedance plethysmography every other day. No prophylaxis used during study. | 349 patients with adequate venographic studies. Venography was unsuccesful due to failure of venous access in 12.6% and was inconclusive in 8.6% of patients in whom it was attempted. | 201 (57.6%) had DVT and 63 (18.1%) proximal DVT. Confirmed PE developed in 7 (2%). Multiple logistic regression identified the following independent factors associated with DVT: age (OR: 1.05 per year), blood transfusion (1.74), surgery (2.30), fracture of femur or tibia (4.82), and spinal-cord injury (8.59).
Venous thromboembolism in the high-risk trauma patient: do risks justify aggressive screening and prophylaxis? | Spain, Richardson, Polk, et al., 1997 | Single cohort Quality Score 1 | Only based on clinical suspicion. Prophylaxis varied. | 280 patients with high-risk criteria included; compared with 2,249 low-risk patients. | DVT at high risk in 12 patients (5%) and low risk in 3 (0.1%, p<0.05). PE in 4 (1.4%) vs. none (p<0.05).
Is deep vein thrombosis surveillance warranted in high-risk trauma patients? | Piotrowski, Alexander, Brandt, et al., 1996 | Single cohort Quality Score 3 | Duplex scan within 48 hours of admission, weekly for 3 weeks, biweekly for 3 weeks, monthly until discharge. Prophylaxis with LDH (46.6%), thromboembolic stockings (74%), or SCD (81.3%). 3.8% no prophylaxis. | 343 patients included. | 20 patients developed DVT (5.8%) and 3 PE (1%). Multivariate analysis revealed age and GCS as independent risk factors for DVT. The cost of the screening program was $18,000 per DVT or 5% of total bed charges.
Silent deep vein thrombosis in immobilized multiple trauma patients. | Kudsk, Fabian, Baum, et al., 1989 | Single cohort Quality Score 2 | Venography between days 7 and 12 after injury. No prophylaxis used. | 39 patients included. | 24 patients developed DVT, 12 proximal DVT. Risk factor for DVT was age.
Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient? | Velmahos, Nigro, Tatevossian, et al., 1998 | Single cohort Quality Score 5 | Duplex scan of proximal legs (popliteal fossa to inguinal ligament) and iliac veins whenever possible. Prophylaxis by LDH, SCD, or both. | 200 patients included. 197 had DVT prophylaxis: 92 (46%) LDH, 195 (97.5%) SCD, 90 (45%) both. | Proximal DVT developed in 26 (13%) patients. Patients with DVT had more severe chest and extremity injuries and required higher levels of PEEP during mechanical support. Combined use of LDH and SCD did not decrease DVT rate any further. 4 (2%) had PE.

Evidence Table 13. Five studies using spinal-cord injury as a risk factor

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Asymptomatic deep venous thrombosis in the trauma patient: Is an aggressive screening protocol justified? | Napolitano, Garlapati, Heard, et al., 1995 | Single cohort Quality Score 2 | Duplex twice weekly. DVT prophylaxis by either LDH or SCD or both according to physician's preference. | 458 patients included. | DVT developed in 45 (10%). 1 PE was found. Multivariate analysis identified age, ISS, RTS, length of stay, and spinal injury to be independently associated with DVT.
Use of low molecular weight heparin in preventing thromboembolism in trauma patients. | Knudson, Morabito, Paiement, et al., 1996 | Randomized controlled trial Quality Score 3 | Duplex on admission and every 5-7 days. Prophylaxis by LMWH, SCD, AVF, or LDH. | 487 patients included, 372 analyzed. 202 were stratified to the heparin group and were randomized to receive LMWH (120) or optimal compression (82) by SCD (61) or foot pumps (21). 170 were stratified to the no-heparin group and received optimal compression. | DVT developed in 9 (2.4%) patients and PE (nonfatal) in 1. In randomized patients, DVT developed in 1 LMWH and 2 compression. 6 more nonrandomized patients of the no-heparin group had DVT.
A prospective study of venous thromboembolism after major trauma. | Geerts, Code, Jay, et al., 1994 | Single cohort Quality Score 5 | Bilateral contrast venography 14-21 days after admission and impedance plethysmography every other day. No prophylaxis used during study. | 349 patients with adequate venographic studies. Venography was unsuccesful due to failure of venous access in 12.6% and was inconclusive in 8.6% of patients in whom it was attempted. | 201 (57.6%) had DVT and 63 (18.1%) proximal DVT. Confirmed PE developed in 7 (2%). Multiple logistic regression identified the following independent factors associated with DVT: age (OR: 1.05 per year), blood transfusion (1.74), surgery (2.30), fracture of femur or tibia (4.82), and spinal-cord injury (8.59).
Is deep vein thrombosis surveillance warranted in high-risk trauma patients? | Piotrowski, Alexander, Brandt, et al., 1996 | Single cohort Quality Score 3 | Duplex scan within 48 hours of admission, weekly for 3 weeks, biweekly for 3 weeks, monthly until discharge. Prophylaxis with LDH (46.6%), thromboembolic stockings (74%), or SCD (81.3%). 3.8% no prophylaxis. | 343 patients included. | 20 patients developed DVT (5.8%) and 3 PE (1%). Multivariate analysis revealed age and GCS as independent risk factors for DVT. The cost of the screening program was $18,000 per DVT or 5% of total bed charges.
Silent deep vein thrombosis in immobilized multiple trauma patients. | Kudsk, Fabian, Baum, et al., 1989 | Single cohort Quality Score 2 | Venography between days 7 and 12 after injury. No prophylaxis used. | 39 patients included. | 24 patients developed DVT, 12 proximal DVT. Risk factor for DVT was age.

Evidence Table 14. Ten studies evaluating age of patients with and without deep venous thrombosis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Deep venous thrombosis in the trauma patient. | Hill, Berry, and Ruiz, 1994 | Prospective comparative cohorts Quality Score 5 | Duplex scans on days 1, 3, 6, 10, 21 or until discharge. Prophylaxis by LDH or nothing. | 100 patients studied. 50 received LDH and 50 did not at the discretion of the surgeon. | 15 patients developed DVT. Only 1 was not receiving prophylaxis. There were more lower extremity injuries and a higher ISS in patients with DVT than in those without DVT.
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Prospective ultrasound evaluation of venous thrombosis in high-risk trauma patients. | Burns, Cohn, Frumento, et al., 1993 | Single cohort Quality Score 2 | Duplex of upper and lower extremities and neck twice weekly until discharge or death. LDH or SCD in most patients. | 57 patients included. | 12 developed DVT (21%) and 2 PE (0.5%). Patients with DVT had older age (39.6 vs. 29.9 years, p<0.05) and higher ISS (20.3 vs. 12.6, p=0.045).
Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. | Dennis, Menawat, Von Thron, et al., 1993 | Prospective comparative cohorts Quality Score 6 | Duplex within 48 hours of admission and every 5 days thereafter. Prophylaxis by SCD or LDH or nothing. | 395 patients included. 281 randomized to receive VT prophylaxis and 114 to no prophylaxis. | DVT developed in 8 patients with prophylaxis and 10 without (2.9 vs. 8.8%, p<0.02). 2 PE in each group. Risk factor of DVT was spinal trauma.
Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. | Upchurch, Demling, Davies, et al., 1995 | Single cohort Quality Score 3 | Duplex on day 5-10 and then at the discretion of surgeon. Prophylaxis by LDH 5,000 SC 12 h or LDH IV or low-dose coumadin or SCD if possible. | 66 patients included. | DVT developed in 13 (19.6%) and PE in 3 (4.5%) patients. 55 of 66 patients (83%) had increased risk for VT (head, spinal-cord, pelvic, or lower extremity trauma). Patients with VT were older and stayed longer in hospital.
Incidence of deep-vein thrombosis in patients with fractures of the lower extremity distal to the hip. | Abelseth, Buckley, Pineo, et al., 1996 | Single cohort Quality Score 4 | Venogram after operative fixation (day 3-22) as outpatient. No prophylaxis. | 102 patients included. | DVT developed in 29 (28%) patients and PE in 2. Risk factors for DVT were age >60, operating room time >105 minutes, time from injury to operation >27 h.
A prospective study of venous thromboembolism after major trauma. | Geerts, Code, Jay, et al., 1994 | Single cohort Quality Score 5 | Bilateral contrast venography 14-21 days after admission and impedance plethysmography every other day. No prophylaxis used during study. | 349 patients with adequate venographic studies. Venography was unsuccesful due to failure of venous access in 12.6% and was inconclusive in 8.6% of patients in whom it was attempted. | 201 (57.6%) had DVT and 63 (18.1%) proximal DVT. Confirmed PE developed in 7 (2%). Multiple logistic regression identified the following independent factors associated with DVT: age (OR: 1.05 per year), blood transfusion (1.74), surgery (2.30), fracture of femur or tibia (4.82), and spinal-cord injury (8.59).
Thromboembolism following multiple trauma. | Knudson, Collins, Goodman, et al., 1992 | Randomized controlled trial Quality Score 1 | Duplex within 24 hours of admission and every 5 days up to 3 weeks or discharge. Prophylaxis by SCD or LDH. | 113 patients included. 76 randomized to SCD and 37 to LDH 5,000 12 h (11 patients with contraindications to LDH were assigned to the SCD group). | VT developed in 12 patients (5 DVT, 4 PE, 3 both); 9 in the SCD group and 3 in the LDH group. Risk factors for VT were age, immobilization, number of transfusions, and clotting abnormalities.
Is deep vein thrombosis surveillance warranted in high-risk trauma patients? | Piotrowski, Alexander, Brandt, et al., 1996 | Single cohort Quality Score 3 | Duplex scan within 48 hours of admission, weekly for 3 weeks, biweekly for 3 weeks, monthly until discharge. Prophylaxis with LDH (46.6%), thromboembolic stockings (74%), or SCD (81.3%). 3.8% no prophylaxis. | 343 patients included. | 20 patients developed DVT (5.8%) and 3 PE (1%). Multivariate analysis revealed age and GCS as independent risk factors for DVT. The cost of the screening program was $18,000 per DVT or 5% of total bed charges.
Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient? | Velmahos, Nigro, Tatevossian, et al., 1998 | Single cohort Quality Score 5 | Duplex scan of proximal legs (popliteal fossa to inguinal ligament) and iliac veins whenever possible. Prophylaxis by LDH, SCD, or both. | 200 patients included. 197 had DVT prophylaxis: 92 (46%) LDH, 195 (97.5%) SCD, 90 (45%) both. | Proximal DVT developed in 26 (13%) patients. Patients with DVT had more severe chest and extremity injuries and required higher levels of PEEP during mechanical support. Combined use of LDH and SCD did not decrease DVT rate any further. 4 (2%) had PE.

Evidence Table 15. Nine studies evaluating Injury Severity Score in patients with and without deep venous thrombosis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Deep venous thrombosis in the trauma patient. | Hill, Berry, and Ruiz, 1994 | Prospective comparative cohorts Quality Score 5 | Duplex scans on days 1, 3, 6, 10, 21 or until discharge. Prophylaxis by LDH or nothing. | 100 patients studied. 50 received LDH and 50 did not at the discretion of the surgeon. | 15 patients developed DVT. Only 1 was not receiving prophylaxis. There were more lower extremity injuries and a higher ISS in patients with DVT than in those without DVT.
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Prospective ultrasound evaluation of venous thrombosis in high-risk trauma patients. | Burns, Cohn, Frumento, et al., 1993 | Single cohort Quality Score 2 | Duplex of upper and lower extremities and neck twice weekly until discharge or death. LDH or SCD in most patients. | 57 patients included. | 12 developed DVT (21%) and 2 PE (0.5%). Patients with DVT had older age (39.6 vs. 29.9 years, p<0.05) and higher ISS (20.3 vs. 12.6, p=0.045).
Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. | Dennis, Menawat, Von Thron, et al., 1993 | Prospective comparative cohorts Quality Score 6 | Duplex within 48 hours of admission and every 5 days thereafter. Prophylaxis by SCD or LDH or nothing. | 395 patients included. 281 randomized to receive VT prophylaxis and 114 to no prophylaxis. | DVT developed in 8 patients with prophylaxis and 10 without (2.9 vs. 8.8%, p<0.02). 2 PE in each group. Risk factor of DVT was spinal trauma.
Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. | Upchurch, Demling, Davies, et al., 1995 | Single cohort Quality Score 3 | Duplex on day 5-10 and then at the discretion of surgeon. Prophylaxis by LDH 5,000 SC 12 h or LDH IV or low-dose coumadin or SCD if possible. | 66 patients included. | DVT developed in 13 (19.6%) and PE in 3 (4.5%) patients. 55 of 66 patients (83%) had increased risk for VT (head, spinal-cord, pelvic, or lower extremity trauma). Patients with VT were older and stayed longer in hospital.
A prospective study of venous thromboembolism after major trauma. | Geerts, Code, Jay, et al., 1994 | Single cohort Quality Score 5 | Bilateral contrast venography 14-21 days after admission and impedance plethysmography every other day. No prophylaxis used during study. | 349 patients with adequate venographic studies. Venography was unsuccessful due to failure of venous access in 12.6% and was inconclusive in 8.6% of patients in whom it was attempted. | 201 (57.6%) had DVT and 63 (18.1%) proximal DVT. Confirmed PE developed in 7 (2%). Multiple logistic regression identified the following independent factors associated with DVT: age (OR: 1.05 per year), blood transfusion (1.74), surgery (2.30), fracture of femur or tibia (4.82), and spinal-cord injury (8.59).
Thromboembolism following multiple trauma. | Knudson, Collins, Goodman, et al., 1992 | Randomized controlled trial Quality Score 1 | Duplex within 24 hours of admission and every 5 days up to 3 weeks or discharge. Prophylaxis by SCD or LDH. | 113 patients included. 76 randomized to SCD and 37 to LDH 5,000 12 h (11 patients with contraindications to LDH were assigned to the SCD group). | VT developed in 12 patients (5 DVT, 4 PE, 3 both); 9 in the SCD group and 3 in the LDH group. Risk factors for VT were age, immobilization, number of transfusions, and clotting abnormalities.
Is deep vein thrombosis surveillance warranted in high-risk trauma patients? | Piotrowski, Alexander, Brandt, et al., 1996 | Single cohort Quality Score 3 | Duplex scan within 48 hours of admission, weekly for 3 weeks, biweekly for 3 weeks, monthly until discharge. Prophylaxis with LDH (46.6%), thromboembolic stockings (74%) or SCD (81.3%). 3.8% no prophylaxis. | 343 patients included. | 20 patients developed DVT (5.8%) and 3 PE (1%). Multivariate analysis revealed age and GCS as independent risk factors for DVT. The cost of the screening program was $18,000 per DVT or 5% of total bed charges.
Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient? | Velmahos, Nigro, Tatevossian, et al., 1998 | Single cohort Quality Score 5 | Duplex scan of proximal legs (popliteal fossa to inguinal ligament) and iliac veins whenever possible. Prophylaxis by LDH, SCD, or both. | 200 patients included. 197 had DVT prophylaxis: 92 (46%) LDH, 195 (97.5%) SCD, 90 (45%) both. | Proximal DVT developed in 26 (13%) patients. Patients with DVT had more severe chest and extremity injuries and required higher levels of PEEP during mechanical support. Combined use of LDH and SCD did not decrease DVT rate any further. 4 (2%) had PE.

Evidence Table 16. Three studies evaluating blood transfusion in patients with and without deep venous thrombosis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Prevention of venous thromboembolism in trauma patients. | Knudson, Lewis, Clinton, et al., 1994 | Randomized controlled trial Quality Score 0 | Duplex within 24 hours of admission and then every 5-7 days for at least 3 weeks. Prophylaxis by LDH, SCD, or nothing. | Patients divided in three groups and randomized within each group. Group I: patients who could receive heparin and SCD were randomized in LDH, 5,000 units SC/12 h, or thigh-length SCD or no prophylaxis. Group II: patients who could not wear SCD were randomized to LDH or no prophylaxis. Group III: patients who could not receive heparin were randomized to SCD or no prophylaxis. | 255 patients analyzed and 15 developed DVT (5.8%). In Group I, the incidence of DVT was the same (2.3% heparin vs. 14.2% SCD vs. 3.2% no prophylaxis). In Group II, the incidence of DVT was the same (5.5% heparin vs. 8% no prophylaxis). In Group III, patients on SCD had lower DVT incidence (0%) than patients without prophylaxis (14.7%). Risk factors for DVT were age >30, immobilization >3 days, pelvic or lower extremity fractures.
Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. | Upchurch, Demling, Davies, et al., 1995 | Single cohort Quality Score 3 | Duplex on day 5-10 and then at the discretion of surgeon. Prophylaxis by LDH 5,000 SC 12 h or LDH IV or low-dose coumadin or SCD if possible. | 66 patients included. | DVT developed in 13 (19.6%) and PE in 3 (4.5%) patients. 55 of 66 patients (83%) had increased risk for VT (head, spinal-cord, pelvic, or lower extremity trauma). Patients with VT were older and stayed longer in hospital.
Thromboembolism following multiple trauma. | Knudson, Collins, Goodman, et al., 1992 | Randomized controlled trial Quality Score 1 | Duplex within 24 hours of admission and every 5 days up to 3 weeks or discharge. Prophylaxis by SCD or LDH. | 113 patients included. 76 randomized to SCD and 37 to LDH 5,000 12 h (11 patients with contraindications to LDH were assigned to the SCD group). | VT developed in 12 patients (5 DVT, 4 PE, 3 both); 9 in the SCD group and 3 in the LDH group. Risk factors for VT were age, immobilization, number of transfusions, and clotting abnormalities.

Evidence Table 17. Three studies comparing methods of screening for deep venous thrombosis

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
D-dimer in the early diagnosis of thromboembolic disease in acute spinal injuries. | Engel, Evans, Mikk, et al., 1993 | Prospective comparative cohorts Quality Score 1 | D-dimer levels twice weekly. Doppler for levels >0.25. Clinical exam for lower levels. Prophylaxis by TED hoses or LDH. | 267 patients included, 103 with elevated values. | 33 of 103 patients had VT; 24 of them had DVT (22 by Doppler or venography, 4 by clinical exam); and 7 had PE (all by clinical exam).
Venous thrombosis in acute spinal cord paralysis. | Brach, Moser, Cedar, et al., 1977 | Single cohort Quality Score 3 | Daily 125 I-fibrinogen test and IP. Venography of tests positive. No mention of prophylaxis. | 10 consecutive patients included. | DVT in 7 (70%) by venography. Fibrinogen test had 2 false positives (9 DVT) and IP had 3 false negatives (4 DVT). PE developed in 1.
Deep venous thrombosis in acute spinal-cord injury: A comparison of 125 I-fibrinogen leg scanning, impedance plethysmography, and venography. | Todd, Frisbie, Rossier, et al., 1976 | Prospective comparative cohorts Quality Score 4 | 125 I-fibrinogen test and IP at different times, followed by venography within 24 hours. No mention of prophylaxis. | 20 patients included. Comparison between tests was done in 17 limbs. | Agreement between venography and fibrinogen scanning was 59% (6 false positive and 1 false negative for fibrinogen). Agreement between IP and venography was 96% (no false positives, 1 false negative).

Evidence Table 18. Six studies reporting on pulmonary embolism and fatal pulmonary embolism after vena cava filter placement

Title | Author(s), Year | Study Design/ Quality Score | Intervention | Description | Results
Efficacy of prophylactic vena cava filters in high-risk trauma patients. | Gosin, Graham, Ciocca, et al., 1997 | Prospective cohorts with retrospective control cohort Quality Score 2 | Screening tests based on clinical suspicion. SCD or LDH or both in patients without VCF. Patients with VCF, no additional prophylaxis. | 250 patients included. VCF in 99. Group compared with 249 historical controls. | PE developed in 4 (1.9%) study patients (no PE in VCF patients, p<0.02) and in 12 (4.8%) historical controls (p<0.05).
Prophylactic vena cava filter insertion in selected high-risk orthopaedic trauma patients. | Rogers, Shackford, Ricci, et al., 1997 | Prospective cohorts with retrospective control cohort Quality Score 4 | Impedance plethysmography weekly. SCD for prophylaxis. | 35 prospectively followed patients had VCF. Group compared with 83 historical controls without VCF. | No PE in VCF patients. 6 (7.1%) PEs in no VCF patients. VCF placement was not associated with many complications: 2 insertion site thrombosis, 1 free floating clot at filter tip (had second filter inserted), one VCF tilting. Two-year VCF patency rate 93.6%.
Prophylactic Greenfield filter placement in selected high-risk trauma patients. | Khansarinia, Dennis, Veldenz, et al., 1995 | Prospective cohorts with retrospective control Quality Score 1 | Duplex, V/Q scan, or angiogram obtained on the basis of clinical symptoms. Prophylaxis by LDH or SCD. | 180 patients included prospectively. They were matched for age, sex, mechanism of injury, ISS, and days in ICU with 216 historical controls not having filters. | PE developed in 13 historical controls (6%) of which 9 (4.2%) were fatal. None of the VCF patients had a PE (p<0.009 for PE, p<0.03 for fatal PE). Six VCF-related complications developed (1 insertion site thrombosis, 1 migration to right ventricle requiring thoracotomy for retrieval, and 4 partial VCF expansions requiring additional VCF placement).
Early placement of prophylactic vena caval filters in injured patients at high risk for pulmonary embolism. | Rodriguez, Lopez, Proctor, et al., 1996 | Prospective cohorts with retrospective control cohort Quality Score 4 | Duplex scan and pulmonary angiography based on clinical indications. | 40 patients with these inclusion criteria were monitored prospectively and had VCFs placed. 80 historical controls matched for mechanism of injury and risk factors who did not have VCF. Prophylaxis in both groups by various methods. | PE was found in 1 patient of the VCF group (2.5%) vs. 14 patients of the no VCF group (17%). No fatal PE in the VCF group but 8 (10%) in the no VCF group. Incidence of DVT was the same: 15% VCF vs. 19% no VCF. Two patients in the VCF group developed significant post-phlebitic syndrome.
Prophylactic vena cava filter insertion in patients with traumatic spinal-cord injury: Preliminary results. | Wilson, Rogers, Wald, et al., 1994 | Prospective cohorts with retrospective control cohort Quality Score 4.5 | Impedance plethysmography weekly. Duplex on abnormal IPG results. SCD or LDH for prophylaxis. | Prospective followup of 15 consecutive patients who received VCF after SCI. Retrospective review of 111 patients who did not have VCF after SCI. | PE was diagnosed in 7 (6.3%) patients with no VCF and was lethal in 3 (2.7%). No PE developed in patients with VCF. One-year VCF patency rate 81.8%.
Greenfield filter prophylaxis of pulmonary embolism in patients undergoing surgery for acetabular fracture. | Webb, Rush, Fuller, et al., 1992 | Single cohort Quality Score 2 | Duplex or venography based on clinical suspicion. Prophylaxis by LDH followed by aspirin. | 51 patients included. 24 had VCF. | PE developed in 2 (7.4%) without VCF (1 fatal) and none with VCF. Leg edema in 2 without VCF and 4 with VCF.