# Bibliography

Abelseth G, Buckley RE, Pineo GE, et al. Incidence of deep-vein thrombosis in patients with fractures of the lower extremity distal to the hip. J Orthop Trauma. 1996;10(4):230-5. [pmid: 8723400].
Agnelli G, Cosmi B, Di Filippo P, et al. A randomised, double-blind, placebo-controlled trial of dermatan sulphate for prevention of deep vein thrombosis in hip fracture. Thromb Haemost. 1992 Feb 3;67(2):203-8.
Agnelli G, Cosmi B, Ranucci V, et al. Impedance plethysmography in the diagnosis of asymptomatic deep vein thrombosis in hip surgery. A venography-controlled study [see comments]. Arch Intern Med. 1991 Nov;151(11):2167-71.
Agnelli G, Ranucci V, Veschi F, et al. Clinical outcome of orthopaedic patients with negative lower limb venography at discharge. Thromb Haemost. 1995 Oct;74(4):1042-4.
Agnelli G, Volpato R, Radicchia S, et al. Accuracy of real-time B-mode ultrasonography in the diagnosis of asymptomatic deep-vein thrombosis in hip surgery patients. Thromb Haemost. 1991;65:1728-32.
Agnelli G, Volpato R, Radicchia S, et al. Detection of asymptomatic deep vein thrombosis by real-time B-mode ultrasonography in hip surgery patients. Thromb Haemost. 1992 Sep 7;68(3):257-60.
Ahlberg A, Nylander G, Robertson B, et al. Dextran in prophylaxis of thrombosis in fractures of the hip. Acta Chir Scand Supp. 1968;387:83-5.
Anglen JO, Bagby C, George R. A randomized comparison of sequential-gradient calf compression with intermittent plantar compression for prevention of venous thrombosis in orthopedic trauma patients: Preliminary results. Am J Orthop. 1998 Jan;27(1):53-8.
Anonymous. Heparin prophylaxis in trauma patients. Am Fam Phys. 1992;45(1).
Anonymous. Prevention of thromboembolism in spinal-cord injury. Consortium for Spinal Cord Medicine. J Spinal Cord Med. 1997 Jul;20(3):259-83.
Autar R. Calculating patients' risk of deep vein thrombosis. Br J Nurs. 1998 Jan 8-21;7(1):7-12. [pmid: 9495950].
Autar R. Nursing assessment of clients at risk of deep vein thrombosis (DVT): The Autar DVT scale. J Adv Nurs. 1996 Apr;23(4):763-70. [pmid: 8675895].
Balbarini A, Rugolotto M, Buttitta F, et al. [Deep venous thrombosis: Epidemiologic, diagnostic, and therapeutic aspects]. [Ita]. Cardiologia. 1998 Jun;43(6):605-15.
Barrellier MT, Bosson JL, Vignon C, et al. [Detection of deep vein thrombosis of the limbs by ultrasound in orthopedic and traumatologic surgery. Results of 1647 studied patients]. [Fre]. Rev Chir Orthop Reparatrice Appar Mot. 1994;80(8):711-9. [pmid: 7638400].
Barrie WW, Wood EH, Crumlish P, et al. Low-dosage ancrod for prevention of thrombotic complications after surgery for fractured neck of femur. BMJ. 1974 Oct 19;4(5937):130-3. [pmcid: 116444].
Barritt DW, Jordan SG. Angicoagulant drugs in the treatment of pulmonary embolism: A controlled trial. Lancet. 1960;I:1309-12.
Barsotti J, Dabo B, Andreu J, et al. [Comparative study of 2 dosages of low molecular weight heparin, PK 10169, in the prevention of thromboembolic incidents during treatment of 103 femur neck fractures]. [Fre]. J Mal Vasc. 1987;12(Suppl B):96-8. [pmid: 2834501].
Becker DM, Gonzalez M, Gentili A, et al. Prevention of deep venous thrombosis in patients with acute spinal cord injuries: Use of rotating treatment tables. Neurosurgery. 1987 May;20(5):675-7.
Bendayan P, Boccalon H. Cost effectiveness of non-invasive tests including Duplex scanning for diagnosis of deep venous thrombosis. A prospective study carried out on 511 patients. Vasa. 1991;20:348-53. [pmid: 1776345].
Bergquist E, Bergqvist D, Bronge A, et al. An evaluation of early thrombosis prophylaxis following fracture of the femoral neck. A comparison between dextran and dicoumarol. Acta Chir Scand. 1972;138(4):689-93. [pmid: 4118601].
Bergqvist D, Flordal PA, Friberg B, et al. Thromboprophylaxis with a low molecular weight heparin (tinzaparin) in emergency abdominal surgery. A double-blind multicenter trial. Vasa. 1996;25(7):156-60. [pmid: 8659218].
Bergqvist D, Fredin H. Pulmonary embolism and mortality in patients with fractured hips-a prospective consecutive series. Eur J Surg. 1991 Oct;157(2):571-4.
Bergqvist D, Kettunen K, Fredin H, et al. Thromboprophylaxis in patients with hip fractures: A prospective, randomized, comparative study between Org 10172 and dextran 70. Surgery. 1991 May;109(5):617-22.
Bergqvist D, Lindblad B. A 30-year survey of pulmonary embolism verified at autopsy: An analysis of 1274 surgical patients. Br J Surg. 1985;72:105-8. [pmid: 3971113].
Bergqvist D, Matzsch T, Burmark US, et al. Low molecular weight heparin given the evening before surgery compared with conventional low-dose heparin in prevention of thrombosis. Br J Surg. 1988;75:888-91. [pmid: 2846113].
Blackshear WM Jr. Noninvasive vascular diagnostic studies in the trauma patient. J Fla Med Assoc. 1983 Jan;70(1):29-33. [pmid: 6827242].
Bosch U, Reilmann H, Sturm J, et al. [Risk of lung embolism following preventive intravenous use of heparin in polytraumatized patients]. [Ger]. Langenbecks Arch Chir. 1988;373(4):214-6. [pmid: 3210844].
Boudaoud L, Roussi J, Lortat-Jacob S, et al. Endothelial fibrinolytic reactivity and the risk of deep venous thrombosis after spinal-cord injury. Spinal Cord. 1997 Mar;35(3):151-7.
Bouderka MA, Sadraoui A, Bouaggad A, et al. [Deep venous thrombosis in head-injured patients: Therapeutic problems]. [Fre]. Cah Anesthesiol. 1996;44(6):513-8.
Brach BB, Moser KM, Cedar L, et al. Venous thrombosis in acute spinal cord paralysis. J Trauma. 1977 Apr;17(4):289-92.
Brandjes DP, Heijboer H, Buller HR, et al. Acenocoumarol and heparin compared with acenocoumarol alone in the initial treatment of proximal-vein thrombosis. N Engl J Med. 1992;327:1485-9. [pmid: 1406880].
Brasel KJ, Borgstrom DC, Weigelt JA. Cost-effective prevention of pulmonary embolus in high-risk trauma patients. J Trauma. 1997 Mar;42(3):456-60; discussion 460-2.
Britt LD, Zolfaghari D, Kennedy E, et al. Incidence and prophylaxis of deep vein thrombosis in a high risk trauma population. Am J Surg. 1996 Jul;172(1):13-4.
Buerger PM, Peoples JB, Lemmon GW, et al. Risk of pulmonary emboli in patients with pelvic fractures. Am Surg. 1993 Aug;59(8):505-8.
Burns GA, Cohn SM, Frumento RJ, et al. Prospective ultrasound evaluation of venous thrombosis in high-risk trauma patients. J Trauma. 1993 Sep;35:405-8. [pmid: 8371299].
Burshtein EM, Kaliteevskii PF. [Analysis of the causes of fatal outcome in fractures of the upper third of the femur]. [Rus]. Klin Med. 1989 Apr;67(4):108-12.
Butson ARC. Intermittent pneumatic calf compression for prevention of deep venous thrombosis in general abdominal surgery. Am J Surg. 1981;142:525-7. [pmid: 7025675].
Cafferata HT, Morrison S, Duer C, et al. Venous thromboembolism in trauma patients: Standardized risk factors. J Vasc Surg. 1998 Aug;28(2):250-9.
Casas ER, Sanchez MP, Arias CR, et al. Prophylaxis of venous thrombosis and pulmonary embolism in patients with acute traumatic spinal cord lesions. Paraplegia. 1977 Nov;15(3):209-14.
Channon GM, Wiley AM. Aspirin prophylaxis of venous thromboembolic disease following fracture of the upper femur. Can J Surg. 1979 Sep;22(5):468-72.
Checketts RG, Bradley JG. Low-dose heparin in femoral neck fractures. Injury. 1974 Aug;6(1):42-4.
Chrisman OD, Snook GA, Wilson TC, et al. Prevention of venous thromboembolism by administration of hydroxychloroquine. A preliminary report. J Bone Joint Surg Am. 1976 Oct;58(7):918-20.
Chu DA, Ahn JH, Ragnarsson KT, et al. Deep venous thrombosis: Diagnosis in spinal cord injured patients. Arch Phys Med Rehabil. 1985 Jun;66(6):365-8.
Cifu DX, Kaelin DL, Wall BE. Deep venous thrombosis: incidence on admission to a brain injury rehabilitation program. Arch Phys Med Rehabil. 1996 Nov;77(11):1182-5.
Clagett GP, Reisch JS. Prevention of venous thromboembolism in general surgical patients. Ann Surg. 1988;208:227-40. [pmid: 2456748]. [pmcid: 1493611].
Clagett GP, Anderson FA, Geerts W, et al. Prevention of venous thromboembolism. Chest. 1998;114:531S-560S. [pmid: 9822062].
Clarke AM, Winson IG. Does plaster immobilization predispose to pulmonary embolism?. Injury. 1992;23(8):533-4. [pmid: 1286905].
Cole CW, Shea B, Bormanis J. Ancrod as prophylaxis or treatment for thromboembolism in patients with multiple trauma. Can J Surg. 1995 Jun;38(3):249-54.
Collins DN, Barnes CL, McCowan TC, et al. Vena caval filter use in orthopaedic trauma patients with recognized preoperative venous thromboembolic disease. J Orthop Trauma. 1992;6(2):135-8. [pmid: 1602331].
Colombani A, Eychenne B, Mericq O, et al. [Pulmonary embolism in orthopedic and traumatology surgery]. [Fre]. Cah Anesthesiol. 1988 Jan-Feb;36(1):53-9.
Comerota AJ, Chouhan V, Harada RN, et al. The fibrinolytic effects of intermittent pneumatic compression. Mechanism of enhanced fibrinolysis. Ann Surg. 1997;226(3):306-14. [pmid: 9339937].
Consensus Conference. Prevention of venous thrombosis and pulmonary embolism. JAMA. 1986;256:744-9. [pmid: 3723773].
Coon WM. The spectrum of pulmonary embolism. Arch Surg. 1976;111:398-402. [pmid: 1259577].
Das Gupta K, Wenda K, Jaeger U, et al. [Color-coded Duplex ultrasound as a screening method in trauma surgery]. [Ger]. Unfallchirurgie. 1995 Jun;21(3):130-6.
Davidson JE, Willms DC, Hoffman MS. Effect of intermittent pneumatic leg compression on intracranial pressure in brain-injured patients. Crit Care Med. 1993 Feb;21(2):224-7.
Demers C, Ginsberg JS, Brill-Edwards P, et al. Heparin and graduated compression stockings in patients undergoing fractured hip surgery. J Orthop Trauma. 1991;5(4):387-91. [pmid: 1761997].
Dennis JW, Menawat S, Von Thron J, et al. Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. J Trauma. 1993 Jul;35(1):132-8; discussion 138-9.
DerSimonian R, Laird NM. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7:177-88. [pmid: 3802833].
Dries DJ. Activation of the clotting system and complement after trauma. New Horizons. 1996;4:276-89. [pmid: 8774802].
Edwards DH, Steel WM, Bentley G. Prophylaxis with dextran 70 against thrombosis in patients with fractures of the upper end of the femur. Injury. 1975 Feb;6(3):250-3.
El Masri WS, Silver JR. Prophylactic anticoagulant therapy in patients with spinal-cord injury. Paraplegia. 1981;19(6):334-42. [pmid: 7312386].
Engel S, Evans SP, Mikk M, et al. D-dimer in the early diagnosis of thromboembolic disease in acute spinal injuries. Med J Aust. 1993 May 17;158(10):705-6.
Eskander MB, Limb D, Stone MH, et al. Sequential mechanical and pharmacological thromboprophylaxis in the surgery of hip fractures. A pilot study. Int Orthop. 1997;21(4):259-61. [pmid: 9349964].
Eskeland G, Solheim K, Skjorten F. Anticoagulant prophylaxis, thromboembolism and mortality in elderly patients with hip fractures. A controlled clinical trial. Acta Chir Scand. 1966 Jan-Feb;131(1):16-29.
Feldman DS, Zuckerman JD, Walters I, et al. Clinical efficacy of aspirin and dextran for thromboprophylaxis in geriatric hip fracture patients. J Orthop Trauma. 1993;7(1):1-5. [pmid: 7679439].
Fisher CG, Blachut PA, Salvian AJ, et al. Effectiveness of pneumatic leg compression devices for the prevention of thromboembolic disease in orthopaedic trauma patients: A prospective, randomized study of compression alone versus no prophylaxis. J Orthop Trauma. 1995 Feb;9(1):1-7.
Fishmann AJ, Greeno RA, Brooks LR, et al. Prevention of deep vein thrombosis and pulmonary embolism in acetabular and pelvic fracture surgery. Clin Orthop. 1994 Aug;(305):133-7. [pmid: 8050222].
Fredin H, Lindblad B, Jaroszewski H, et al. Prevention of thrombosis after hip fracture surgery. Comparison of dextran 70 with and without dihydroergotamine. Acta Chir Scand. 1985;151(8):681-4. [pmid: 2420105].
Fredin HO, Nillius SA, Bergqvist D. Prophylaxis of deep vein thrombosis in patients with fracture of the femoral neck: A prospective comparison between dextran and a sulphated polysaccharide. Acta Orthop Scand. 1982 Jun;53(3):413-7.
Frezza EE, Siram SM, Van Thiel DH, et al. Venous thromboembolism after penetrating chest trauma is not a cause of early death. J Cardiovasc Surg. 1996;37(5):521-4. [pmid: 8941696].
Frisbie JH, Sasahara AA. Low dose heparin prophylaxis for deep venous thrombosis in acute spinal-cord injury patients: A controlled study. Paraplegia. 1981;19(6):343-6. [pmid: 7031568].
Fujii Y, Mammen EF, Farag A, et al. Thrombosis in spinal-cord injury. Thromb Res. 1992 Dec 1;68(4-5):357-68.
Fullen WD, Miller EH, Steele WF, et al. Prophylactic vena caval interruption in hip fractures. J Trauma. 1973 May;13(5):403-10.
Galasko CS, Edwards DH, Fearn CB, et al. The value of low dosage heparin for the prophylaxis of thromboembolism in patients with transcervical and intertrochanteric femoral fractures. Acta Orthop Scand. 1976 Jun;47(3):276-82.
Gatterer R, Wruhs O, Havelec L, et al. [Prevention of thromboembolism in accident surgery-angiospastic complications with DHE-heparin. A multicenter study]. [Ger]. Unfallchirurgie. 1987 Oct;13(5):263-70.
Geerts WH, Code KI, Jay RM, et al. A prospective study of venous thromboembolism after major trauma [see comments]. N Engl J Med. 1994 Dec 15;331:1601-6.
Geerts WH, Jay RM, Code KI, et al. A comparison of low-dose heparin with low-molecular-weight heparin as prophylaxis against venous thromboembolism after major trauma [see comments]. N Engl J Med. 1996 Sep 5;335(10):701-7.
Gehling H, Giannadakis K, Lefering R, et al. [Prospective randomized pilot study of ambulatory prevention of thromboembolism. 2 times 500 mg aspirin (ASS) vs. clivarin 1750]. Unfallchirurg. 1998;101(1):42-9. [pmid: 9522671].
Gent M, Hirsh J, Ginsberg JS, et al. Low-molecular-weight heparinoid orgaran is more effective than aspirin in the prevention of venous thromboembolism after surgery for hip fracture. Circulation. 1996 Jan 1;93(1):80-4.
Gergen M. [Fatal complications of femoral neck fracture with special reference to pulmonary embolism]. [Ger]. Chirurg. 1969 Mar;40(3):135-8. [pmid: 5352248].
Gergen M, Spenrath I, Wagner E. [Nature and prevention of thromboembolism in accident surgery]. [Ger]. Chirurg. 1968 Aug;39(8):366-8.
Gerhart TN, Yett HS, Robertson LK, et al. Low-molecular-weight heparinoid compared with warfarin for prophylaxis of deep-vein thrombosis in patients who are operated on for fracture of the hip. A prospective, randomized trial. J Bone Joint Surg Am. 1991 Apr;73(4):494-502.
Gersin K, Grindlinger GA, Lee V, et al. The efficacy of sequential compression devices in multiple trauma patients with severe head injury [see comments]. J Trauma. 1994 Aug;37(2):205-8.
Gillies TE, Ruckley CV, Nixon SJ. Still missing the boat with fatal pulmonary embolism. Br J Surg. 1996 Oct;83(10):1394-5.
Gold MR, Siegel JE, Russell LB, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Gosin JS, Graham AM, Ciocca RG, et al. Efficacy of prophylactic vena cava filters in high-risk trauma patients. Ann Vasc Surg. 1997 Jan;11(1):100-5.
Gottschalk A, Bisesi MA, Stein PD. Ventilation-perfusion lung scans for the diagnosis of acute pulmonary embolism. In: Hull RD, Raskob GE, Pineo GF, editors. Venous thromboembolism: An evidence-based atlas. Armonk, NY: Futura Publishing Co.; 1996.
Green D. Standard versus low molecular weight heparin in the prevention of thromboembolism in spinal-cord injury. J Rehabil Res Dev. 1991;28(1):426-7.
Green D, Chen D, Chmiel JS, et al. Prevention of thromboembolism in spinal-cord injury: Role of low molecular weight heparin. Arch Phys Med Rehabil. 1994 Mar;75(3):290-2.
Green D, Lee MY, Ito VY, et al. Fixed- vs adjusted-dose heparin in the prophylaxis of thromboembolism in spinal-cord injury. JAMA. 1988 Sep 2;260(9):1255-8.
Green D, Lee MY, Lim AC, et al. Prevention of thromboembolism after spinal-cord injury using low-molecular-weight heparin [see comments]. Ann Intern Med. 1990 Oct 15;113:571-4.
Green D, Rossi EC, Yao JS, et al. Deep vein thrombosis in spinal-cord injury: Effect of prophylaxis with calf compression, aspirin, and dipyridamole. Paraplegia. 1982 Aug;20(4):227-34.
Green D, Twardowski P, Wei R, et al. Fatal pulmonary embolism in spinal-cord injury. Chest. 1994 Mar;105(3):853-5.
Greenfield LJ, Proctor MC, Rodriguez JL, et al. Posttrauma thromboembolism prophylaxis. J Trauma. 1997 Jan;42(1):100-3.
Gruber UF. Prevention of fatal postoperative pulmonary embolism by heparin dihydroergotamine or Dextran 70. Br J Surg. 1982 Jun;69 Suppl:S54-S58. [pmid: 6177371].
Gruber UF Prevention of fatal pulmonary embolism in patients with fractures of the neck of the femur Surg Gynecol Obstet 1985 Jul 161(1) 37 42View this and related citations using 2409613
Gruber UF, Thoni F. Prevention of thrombo-embolic complications in paraplegics. Paraplegia. 1985 Apr;23(2).
Gruen GS, McClain EJ, Gruen RJ. The diagnosis of deep vein thrombosis in the multiply injured patient with pelvic ring or acetabular fractures. Orthopedics. 1995 Mar;18(3):253-7.
Guell Fortuny J, Torras Barba J, Pales Argullos A. [Medico-economic analysis of antithrombotic prophylaxis versus no prophylaxis in traumatology. Study of 920 cases]. [Spa]. Angiologia. 1987 Jan-Feb;39(1):1-8.
Habscheid W, Spannagel U, Kujath P, et al. [Prevention of thrombosis with low molecular weight heparin in ambulatory patients with injury of the lower extremity: An ultrasound study]. [Ger]. Vasa Supp. 1991;33:222-3.
Hachen HJ. Prevention of thromboembolism in paraplegics. [Fre]. Agressologie. 1983 Nov;24(10):527-30. [pmid: 6670682].
Haentjens P. Thromboembolic prophylaxis in orthopaedic trauma patients: A comparison between a fixed dose and an individually adjusted dose of a low molecular weight heparin (nadroparin calcium) [see comments]. Injury. 1996 Jul;27(6):385-90.
Halstuk K, Mahler D, Baker WH. Late sequelae of deep venous thrombosis: Diagnostic and therapeutic considerations. Am J Surg. 1984;147:216-20. [pmid: 6696194].
Hamilton HW, Crawford JS, Gardiner JH, et al. Venous thrombosis in patients with fracture of the upper end of the femur. A phlebographic study of the effect of prophylactic anticoagulation. J Bone Joint Surg Br. 1970 May;52(2):268-89.
Hammers LW, Cohn SM, Brown JM, et al. Doppler color flow imaging surveillance of deep vein thrombosis in high-risk trauma patients. J Ultrasound Med. 1996 Jan;15(1):19-24.
Hansen EH, Jessing P, Lindewald H, et al. Hydroxychloroquine sulphate in prevention of deep venous thrombosis following fracture of the hip, pelvis, or thoracolumbar spine. J Bone Joint Surg Am. 1976 Dec;58(8):1089-93.
Harris S, Chen D, Green D. Enoxaparin for thromboembolism prophylaxis in spinal injury: Preliminary report on experience with 105 patients. Am J Phys Med Rehabil. 1996 Sep-Oct;75(5):326-7.
Hartung B, Schreiber U, Rodiger H. [Study of the platelet aggregation inhibitor MICRISTIN as to its efficacy in the prevention of thromboembolism in the posteroperative phase following surgical interventions]. [Ger]. Folia Haematol. 1979;106(5-6):810-27.
Headrick JR Jr., Barker DE, Pate LM, et al. The role of ultrasonography and inferior vena cava filter placement in high-risk trauma patients. Am Surg. 1997 Jan;63(1):1-8.
Hess P, Oertli D, Durig M, et al. The prevention of thromboembolism in hip traumatology: Low molecular weight heparin versus dextran. Helv Chir Acta. 1992;58(6):931-5. [pmid: 1379576].
Hill SL, Berry RE, Ruiz AJ. Deep venous thrombosis in the trauma patient. Am Surg. 1994 Jun;60(6):405-8.
Hjelmstedt A, Bergvall U. Incidence of thrombosis in patients with tibial fractures. Acta Chir Scand. 1968;134(3):209-18. [pmid: 5730892].
Hoffman R, Largiader F, Brutsch HP. [Perioperative prevention of thromboembolism with low molecular weight heparin and postoperative bleeding complications]. [Ger]. Langenbecks Archiv Chir. 1990;(Suppl II):1179-84.
Hull RD, Raskob GE, Hirsh J, et al. Continuous intravenous heparin compared with intermittent subcutaneous heparin in the initial treatment of proximal-vein thrombosis. N Engl J Med. 1986;315:1109-14. [pmid: 3531862].
Hull RD, Raskob GE, Pineo GF, editors. Venous thromboembolism: An evidence-based atlas. Armonk, NY: Futura Publishing Co.; 1996.
Hull RD, Raskob GE, Rosenbloom D, et al. Heparin for 5 days as compared with 10 days in the initial treatment of proximal venous thrombosis. N Engl J Med. 1990;322:1260-4. [pmid: 2183055].
Isaacs C, Paltiel O, Blake G, et al. Age-associated risks of prophylactic anticoagulation in the setting of hip fracture. Am J Med. 1994 Jun;96(6):487-91.
Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of randomized clinical trials: Is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jorgensen PS, Knudsen JB, Broeng L, et al. [The thromboprophylactic effect of low molecular weight heparin (Fragmin) in hip fracture surgery. A placebo controlled trial]. [Dan]. Ugeskr Laeger. 1993 Mar 8;155(10):706-8.
Jorgensen PS, Knudsen JB, Broeng L, et al. The thromboprophylactic effect of a low-molecular-weight heparin (Fragmin) in hip fracture surgery. A placebo-controlled study. Clin Orthop Rel Res. 1992 May;278:95-100.
Kakkar VV, Cohen AT, Edmonson RA, et al. Low molecular weight heparin versus standard heparin for prevention of venous thromboembolism after major abdominal surgery. Lancet. 1993;341:259-65. [pmid: 8093915].
Kakkar VV, Corrigan TP, Fossard DP. Prevention of fatal postoperative pulmonary embolism by low doses of heparin. An international multicentre trial. Lancet. 1975;7:45-51.
Kaufman HH, Satterwhite T, McConnell BJ, et al. Deep vein thrombosis and pulmonary embolism in head injured patients. Angiology. 1983 Oct;34(10):627-38.
Khansarinia S, Dennis JW, Veldenz HC, et al. Prophylactic Greenfield filter placement in selected high-risk trauma patients. J Vasc Surg. 1995 Sep;22(3):231-5; discussion 235-6.
Kim SW, Charallel JT, Park KW, et al. Prevalence of deep venous thrombosis in patients with chronic spinal-cord injury. Arch Phys Med Rehabil. 1994;75(9):965-8. [pmid: 8085931].
Kinney TB, Rose SC, Valji K, et al. Does cervical spinal-cord injury induce a higher incidence of complications after prophylactic Greenfield inferior vena cava filter usage? [see comments]. J Vasc Interv Radiol. 1996 Nov-Dec;7(6):907-15.
Kiviluoto O, Julkunen H, Honkonen K. [Prevention of venous thromboemboli with low doses of heparin in patients with proximal femur fractures]. [Ger]. Zentralbl Chir. 1980;5(7):460-4.
Kleinschmidt S, Seyfert UT. Heparin-induced thrombocytopenia (HAT)-Still a diagnostic and therapeutical problem in clinical practice. Angiology. 1995;46(1):37-44. [pmid: 7818155].
Knudson MM, Collins JA, Goodman SB, et al. Thromboembolism following multiple trauma. J Trauma. 1992 Jan;32(1):2-11.
Knudson MM, Lewis FR, Clinton A, et al. Prevention of venous thromboembolism in trauma patients. J Trauma. 1994 Sep;37(3):480-7.
Knudson MM, Morabito D, Paiement GD, et al. Use of low molecular weight heparin in preventing thromboembolism in trauma patients. J Trauma. 1996 Sep;41(3):446-59.
Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. [Ambulatory prevention of thrombosis with low molecular weight heparin in plaster immobilization of the lower extremity]. [Ger]. Vasa. 1992;(Suppl);35:105-6.
Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. [Ambulatory prevention of thrombosis with low molecular weight heparin in plaster immobilization of the lower extremity (see comments)]. [Ger]. Chirurg. 1993 Jun;64(6):483-91.
Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. Implementing ambulatory prevention of thrombosis with low molecular weight heparin in plaster immobilization of the lower extremity. [Ger]. Unfallchirurgie. 1994 Dec;20(6):319-28.
Kock HJ, Schmitt-Neuerburg KP, Hanke J, et al. Prophylaxis of venous thromboembolism with low molecular weight heparin in surgical outpatients with immobilization of the lower limb by plaster cast. Hamostaseologie. 1993;13(Suppl):S36-S39.
Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. Thromboprophylaxis with low-molecular-weight heparin in outpatients with plaster-cast immobilization of the leg. Lancet. 1995 Aug 19;346(8973):459-61.
Korvald E, Storen EJ, Ongre A. Simultaneous use of warfarin-sodium and dextran 70 to prevent post-operative venous thrombosis in patients with hip fractures. A controlled trial. J Oslo City Hosp. 1973 Feb;23(2):25-34.
Krasuski M, Jagodzinksi K, Kiwerski JE, et al. Pulmonary embolism as one cause of death after spinal injury-the role of clexane. [Pol]. Chir Narzadow Ruchu Ortop Pol. 1998;63(2):125-31. [pmid: 9684495].
Kriemer-Nielsen H, Husted SE, Krusell LR, et al. Silent pulmonary embolism in patients with deep venous thrombosis. Incidence and fate in a randomized, controlled trial of anticoagulation versus no anticoagulation. J Intern Med. 1994;235:457-61. [pmid: 8182402].
Kruger-Franke M, Hagena FW, Weber W. [Thromboembolism complications in orthopedics and traumatology. A prospective study of 598 operated patients]. [Ger]. Aktuel Traumatol. 1992 Jun;22(3):114-9.
Kudsk KA, Fabian TC, Baum S, et al. Silent deep venous thrombosis in immobilized multiple trauma patients. Am J Surg. 1989 Dec;158(6):515-9.
Kujath P, Spannagel U, Habscheid W. Incidence and prophylaxis of deep venous thrombosis in outpatients with injury of the lower limb. Haemostasis. 1993 Mar;23(Suppl 1):20-6.
Kulkarni JR, Burt AA, Tromans AT, et al. Prophylactic low dose heparin anticoagulant therapy in patients with spinal cord injuries: A retrospective study. Paraplegia. 1992 Mar;30(3):169-72.
Lahnborg G. Effect of low-dose heparin and dihydroergotamine on frequency of postoperative deep-vein thrombosis in patients undergoing post-traumatic hip surgery. Acta Chir Scand. 1980;14(5):319-22. [pmid: 7468062].
Lai JM, Yablon SA, Ivanhoe CB. Incidence and sequelae of symptomatic venous thromboembolic disease among patients with traumatic brain injury. Brain Injury. 1997 May;11(5):331-4.
Laird NM, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6:5-30. [pmid: 2361819].
Lassen MR, Borris LC, Christiansen HM, et al. Prevention of thromboembolism in hip-fracture patients. Comparison of low-dose heparin and low-molecular-weight heparin combined with dihydroergotamine. Arch Orthop Trauma Surg. 1989;108(1):10-3. [pmid: 2913977].
Laureillard C, Latour G, Barre G. Preventive treatment of deep venous thrombosis after orthopedic and traumatologic surgery. Ann Readaptation Med Physique. 1991;34(3):253-9.
Lavrinovich TS, Petukhova LI, Slutskii LI. [Comparative evaluation of aspirin and indirect-action anticoagulants in the prevention of venous thromboses in traumatology and orthopedic practice]. [Rus]. Ortop Travmatol Protez. 1976 Oct;10:35-9. [pmid: 1004825].
Lavrinovich TS, Petukhova LI, Slutskii LI. [Clinical trial of indirect-action anticoagulants in orthopedics and traumatology]. [Rus]. Ortop Travmatol Protez. 1976 Mar;3:32-5. [pmid: 790254].
Lavrinovitsch TS, Petuchova LI, Slutskii LI. [A comparative investigation of acetylsalicyclic acid and indirect anticoagulants for the prophylaxis of venous thromboses in patients with an orthopedic-traumatologic case history (author's transl)]. [Ger]. Z Orthop Ihre Grenzgeb. 1976 Oct;114(5):769-72.
Lawrence JC, Xabregas A, Gray L, et al. Seasonal variation in the incidence of deep vein thrombosis. Br J Surg. 1977 Nov;64(11):777-80.
LeMoine JR, Moser KM. Leg scanning with radioisotope-labeled fibrinogen in patients undergoing hip surgery. Comparison with contrast phlebography and lung scans. JAMA. 1980 May 23-30;243(20):2035-7.
Lensing AWA, Davidson BL, Prins MH, et al. Diagnosis of deep vein thrombosis with ultrasound imaging in symptomatic and asymptomatic high-risk patients. In: Hull RD, Raskob GE, Pineo GF, editors. Venous thromboembolism: An evidence-based atlas. Armonk, NY: Futura Publishing Co.; 1996.
Leroy J, Leclerc MH, Delahousse B, et al. Treatment of heparin-associated thrombocytopenia and thrombosis with low molecular weight heparin (CY 216). Sem Thromb Hemost. 1985 Jul;11(3):326-9.
Lindblad B, Eriksson A, Bergqvist D. Autopsy-verified pulmonary embolism in a surgical department: Analysis of the period from 1951 to 1988. Br J Surg. 1991;78:849-52. [pmid: 1873716].
Lowe GD, Campbell AF, Meek DR, et al. Subcutaneous ancrod in prevention of deep-vein thrombosis after operation for fractured neck of femur. Lancet. 1978 Sep 30;2(8092 Pt 1):698-700.
Massaia Lamberti G, Roveda G, Rossi N, et al. [Closed abdominal injuries]. [Ita]. Min Chir. 1997 Mar;52(3):235-41.
Meden-Britth G, Teien AN. Infusion of purified antithrombin III to patients with fracture of the neck of the femur. Eur Surg Res. 1979;11(4):289-95. [pmid: 527616].
Meredith JW, Young JS, O'Neil EA, et al. Femoral catheters and deep venous thrombosis: A prospective evaluation with venous Duplex sonography. J Trauma. 1993 Aug;35(2):187-90; discussion 190-1.
Merli GJ, Crabbe S, Doyle L, et al. Mechanical plus pharmacological prophylaxis for deep vein thrombosis in acute spinal-cord injury. Paraplegia. 1992 Aug;30(8):558-62.
Merli GJ, Doyle L, Crabbe S, et al. Prophylaxis for deep vein thrombosis in acute spinal-cord injury comparing two doses of low molecular weight heparinoid in combination with external pneumatic compression. J Rehabil Res Dev. 1991;28(1):434-5.
Merli GJ, Herbison GJ, Ditunno JF, et al. Deep vein thrombosis: Prophylaxis in acute spinal cord injured patients. Arch Phys Med Rehabil. 1988 Sep;69(9):661-4.
Meyer CS, Blebea J, Davis K Jr., et al. Surveillance venous scans for deep venous thrombosis in multiple trauma patients. Ann Vasc Surg. 1995 Jan;9(1):109-14.
Meythaler JM, DeVivo MJ, Hayne JB. Cost-effectiveness of routine screening for proximal deep venous thrombosis in acquired brain injury patients admitted to rehabilitation [see comments]. Arch Phys Med Rehabil. 1996 Jan;77(1):1-5.
Micheli LJ. Thromboembolic complications of cast immobilization for injuries of the lower extremities. Clin Orthop Rel Res. 1975 May;108:191-5.
Mironov SP, Burmakova GM, Fedotova TM. [The use of fraxiparin in orthopedic trauma patients to prevent and treat pulmonary embolism and deep venous thrombosis of the extremities]. [Rus]. Ter Arkh. 1993;65(10):82-3.
Mitra AK, Khoo TK, Ngan CC. Deep-vein thrombosis following hip surgery for fracture of the proximal femur. Singapore Med J. 1989 Dec;30(6):530-4.
Moher D, Jadad AR, Klassen TP. Does quality of reports of randomized trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
Monreal M, Lafoz E, Navarro A, et al. A prospective double-blind trial of a low molecular weight heparin once daily compared with conventional low-dose heparin three times daily to prevent pulmonary embolism and venous thrombosis in patients with hip fracture [see comments]. J Trauma. 1989 Jun;29(6):873-5.
Monreal M, Lafoz E, Salvador R, et al. Adverse effects of three different forms of heparin therapy: Thrombocytopenia, increased transaminases, and hyperkalaemia. Eur J Clin Pharmacol. 1989;37(4):415-8. [pmid: 2557219].
Montgomery KD, Potter HG, Helfet DL. Magnetic resonance venography to evaluate the deep venous system of the pelvis in patients who have an acetabular fracture. J Bone Joint Surg Am. 1995 Nov;77(11):1639-49.
Montgomery KD, Potter HG, Helfet DL. The detection and management of proximal deep venous thrombosis in patients with acute acetabular fractures: A follow-up report. J Orthop Trauma. 1997 Jul;11(5):330-6.
Montrey JS, Kistner RL, Kong AY, et al. Thromboembolism following hip fracture. J Trauma. 1985 Jun;25(6):534-7.
Morris GK, Mitchell JR. Preventing venous thromboembolism in elderly patients with hip fractures: Studies of low-dose heparin, dipyridamole, aspirin, and flurbiprofen. BMJ. 1977 Feb 26;1(6060):535-7. [pmcid: 30582].
Morris GK, Mitchell JRA. Warfarin sodium in prevention of deep venous thrombosis and pulmonary embolism in patients with fractured neck of the femur. Lancet. 1976 Oct 23;2(7991):869-72.
Myhre HO, Storen EJ, Auensen CA. Pre- or post-operative start of anticoagulation prophylaxis in patients with fractured hips?. J Oslo City Hosp. 1973 Jan;23(1):15-23.
Myllynen P, Kammonen M, Rokkanen P, et al. Deep venous thrombosis and pulmonary embolism in patients with acute spinal-cord injury; A comparison with nonparalyzed patients immobilized due to spinal fractures. J Trauma. 1985 Jul;25(6):541-3.
Myrvold HE, Persson JE, Svensson B, et al. Prevention of thrombo-embolism with dextran 70 and heparin in patients with femoral neck fractures. Acta Chir Scand. 1973;139(7):609-16. [pmid: 4768533].
Napolitano LM, Garlapati VS, Heard SO, et al. Asymptomatic deep venous thrombosis in the trauma patient: Is an aggressive screening protocol justified?. J Trauma. 1995 Oct;39(4):651-7; discussion 657-9.
Nicolaides AN. Small doses of subcutaneous sodium heparin in preventing deep thrombosis after major surgery. Lancet. 1972;2:890-3. [pmid: 4116600].
Nicolaides AN, Miles C, Hoare M, et al. Intermittent sequential pneumatic compression of the legs and thromboembolism-deterrent stockings in the prevention of postoperative deep venous thrombosis. Surgery. 1983;94(1):21-5. [pmid: 6857507].
Norcross ED, Alexander JB, O'Malley KF, et al. The failure of serial pneumatic cuff venous occlusion plethysmography to predict patients at risk for pulmonary emboli after trauma. Am Surg. 1991 Mar;57(3):169-70.
Normand R, Mathieu JP. Prevention of venous thromboses under plaster casts after leg injury. Comparison of heparin-calcium and pentosan sulfuric polyester. [Fre]. Cah Anesthesiol. 1987 Nov;35(7):559-62.
Nunn CR, Neuzil D, Naslund T, et al. Cost-effective method for bedside insertion of vena caval filters in trauma patients [see comments]. J Trauma. 1997 Nov;43(5):752-8.
O'Donnell TF Jr, Browse NL, Burnand KG, et al. The socioeconomic effects of an iliofemoral venous thrombosis. J Surg Res. 1977 May;22(5):483-8.
Oertli D, Hess P, Durig M, et al. Prevention of deep vein thrombosis in patients with hip fractures: Low molecular weight heparin versus dextran. World J Surg. 1992 Sep-Oct;16(5):980-4; discussion 984-5.
O'Malley KF, Ross SE. Pulmonary embolism in major trauma patients. J Trauma. 1990 Jun;30(6):748-50.
Orthner E, Hertz H, Kwasny O, et al. [Prevention of thromboembolism in para-articular femoral fractures of the hip-results of a prospective randomized study of heparin-DHE and ASS-DHE]. [Ger]. Unfallchirurgie. 1990 Jun;16(3):128-38.
Oster G, Tuden RL, Colditz GA. A cost-effectiveness analysis of prophylaxis against deep-vein thrombosis in major orthopedic surgery. JAMA. 1987 Jan 9;257(2):203-8.
Owings JT, Bagley M, Gosselin R, et al. Effect of critical injury on plasma antithrombin activity: Low antithrombin levels are associated with thromboembolic complications. J Trauma. 1996 Sep;41(3):396-405.
Owings JT, Kraut E, Battistella F, et al. Timing of the occurrence of pulmonary embolism in trauma patients. Arch Surg. 1997 Aug;132(8):862-6; discussion 866-7.
Pachter HL, Riles TS. Low dose heparin: Bleeding and wound complications in the surgical patient. A prospective randomized study. Ann Surg. 1977;186(6):669-74. [pmid: 603271].
Paiement GD. Thromboembolic complications following trauma surgery: Incidence and outcomes. Orthopedics. 1995 Jul;18(Suppl):12-4. [pmid: 7479419].
Patton JH Jr., Fabian TC, Croce MA, et al. Prophylactic Greenfield filters: Acute complications and long-term follow-up [see comments]. J Trauma. 1996 Aug;41(2):231-6; discussion 236-7.
Perkash A, Prakash V, Perkash I. Experience with the management of thromboembolism in patients with spinal-cord injury: Part I, Incidence, diagnosis, and role of some risk factors. Paraplegia. 1978 Nov;16(3):322-31.
Pini M, Spadini E, Carluccio L, et al. Dextran/aspirin versus heparin/dihydroergotamine in preventing thrombosis after hip fractures. J Bone Joint Surg Br. 1985 Mar;67(2):305-9.
Pini M, Tagliaferri A, Manotti C, et al. Low molecular weight heparin (Alfa LHWH) compared with unfractionated heparin in prevention of deep-vein thrombosis after hip fractures. Int Angiol. 1989 Jul-Sep;8(3):134-9.
PIOPED investigators. Value of the ventilation/perfusion scan in acute pulmonary embolism-results of the prospective investigation of pulmonary embolism diagnosis (PIOPED). JAMA. 1990;263:2753-9. [pmid: 2332918].
Piotrowski JJ, Alexander JJ, Brandt CP, et al. Is deep vein thrombosis surveillance warranted in high-risk trauma patients?. Am J Surg. 1996 Aug;172(2):210-3.
Platz A, Hoffmann R, Kohler A, et al. [Prevention of thromboembolism in hip fracture: Unfractionated heparin versus low molecular weight heparin (a prospective, randomized study)]. [Ger]. Z Unfallchir Versicherungsmed. 1993;86(3):184-8. [pmid: 8130009].
Powers PJ, Gent M, Jay RM, et al. A randomized trial of less intense postoperative warfarin or aspirin therapy in the prevention of venous thromboembolism after surgery for fractured hip. Arch Int Med. 1989 Apr;149(4):771-4.
Roberts TS, Nelson CL, Barnes CL, et al. The preoperative prevalence and postoperative incidence of thromboembolism in patients with hip fractures treated with dextran prophylaxis. Clin Orthop Rel Res. 1990 Jun;255:198-203.
Rodriguez JL, Lopez JM, Proctor MC, et al. Early placement of prophylactic vena caval filters in injured patients at high risk for pulmonary embolism. J Trauma. 1996 May;40(5):797-802; discussion 802-4.
Rogers FB, Shackford SR, Ricci MA, et al. Prophylactic vena cava filter insertion in selected high-risk orthopaedic trauma patients. J Orthop Trauma. 1997 May;11(4):267-72.
Rogers FB, Shackford SR, Ricci MA, et al. Routine prophylactic vena cava filter insertion in severely injured trauma patients decreases the incidence of pulmonary embolism [see comments]. J Am Coll Surg. 1995 Jun;180(6):641-7.
Rogers FB, Shackford SR, Wilson J, et al. Prophylactic vena cava filter insertion in severely injured trauma patients: Indications and preliminary results. J Trauma. 1993 Oct;35(4):637-41; discussion 641-2.
Rogers FB, Strindberg G, Shackford SR, et al. Five-year follow-up of prophylactic vena cava filters in high-risk trauma patients. Arch Surg. 1998 Apr;133(4):406-11; discussion 412.
Rorbaek-Madsen M, Jakobsen BW, Pedersen J, et al. Dihydroergotamine and the thromboprophylactic effect of dextran 70 in emergency hip surgery. Br J Surg. 1988 Apr;75(4):364-5.
Rosenthal D, McKinsey JF, Levy AM, et al. Use of the Greenfield filter in patients with major trauma. Cardiovasc Surg. 1994 Feb;2(1):52-5.
Rubio PA. Percutaneously placed inferior vena cava filter for the prevention of pulmonary emboli: A plea for early insertion. Int Surg. 1993 Oct-Dec;78(4):328-31. [pmid: 8175262].
Ruiz AJ, Hill SL, Berry RE. Heparin, deep venous thrombosis, and trauma patients [see comments]. Am J Surg. 1991 Aug;162(2):159-62.
Sackett DL. How to read clinical journals: I-V. Can Med Assoc J. 1981;124:695-750.
Salzman EW, Harris WH, DeSanctis RW. Anticoagulation for prevention of thromboembolism following fractures of the hip. N Engl J Med. 1966 Jul 21;275(3):122-30.
Satiani B, Falcone R, Shook L, et al. Screening for major deep vein thrombosis in seriously injured patients: A prospective study. Ann Vasc Surg. 1997 Nov;11(6):626-9.
Schlag G, Gaudernak T, Pelinka H, et al. Thromboembolic prophylaxis in hip fracture. Acta Orthop Scand. 1986 Aug;57(4):340-3.
Schmidt U, Enderson BL, Chen JP, et al. D-dimer levels correlate with pathologic thrombosis in trauma patients. J Trauma. 1992 Aug;33(2):312-9; discussion 319-20.
Schott G, Elsel W, Mockel G, et al. Prevention of thromboembolism with heparin and dihydroergotamine in a trauma surgery patient sample-comparison of the effectiveness of different administration forms of dihydroergotamine. [Ger]. Z Arztl Fortbild. 1992 Oct 12;86(19):973-6.
Seglias J, Gruber UF. Dosage in low-dose heparin prophylaxis. Haemostasis. 1979;8(6):361-72. [pmid: 511015].
Sethi H, Alving B. Venous thromboembolism after major trauma. Trauma. 1998;40(3):23-34.
Setti M, Nespoli M, De Giacomi D, et al. Prophylaxis of thrombo/embolic complications in hip surgery. Ital J Orthop Traumatol. 1981 Apr;7(1):99-102.
Shackford SR, Davis JW, Hollingsworth-Fridlund P, et al. Venous thromboembolism in patients with major trauma. Am J Surg. 1990 Apr;159(4):365-9.
Sharnoff JG, Rosen RL, Sadler AH, et al. Prevention of fatal pulmonary thromboembolism by heparin prophylaxis after surgery for hip fractures. J Bone Joint Surg Am. 1976 Oct;58(7):913-8.
Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias: Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
Silver JR. The prophylactic use of anticoagulant therapy in the prevention of pulmonary emboli in one hundred consecutive spinal injury patients. Paraplegia. 1974 Nov;12(3):188-96. [pmid: 4453423].
Silverstein MD, Heit JA, Mohr DN, et al. Trends in the incidence of deep vein thrombosis and pulmonary embolism. A 25-year population-based study. Arch Intern Med. 1998;158:585-93. [pmid: 9521222].
Smith EB. Pulmonary embolism-A concept for survival. J Natl Med Assoc. 1991 Mar;83(3):255-7. [pmid: 2038086].
Snook GA, Chrisman OD, Wilson TC. Thromboembolism after surgical treatment of hip fractures. Clin Orthop Rel Res. 1981 Mar-Apr;155:21-4.
Spain DA, Bergamini TM, Hoffmann JF, et al. Comparison of sequential compression devices and foot pumps for prophylaxis of deep venous thrombosis in high-risk trauma patients. Am Surg. 1998 Jun;64(6):522-5; discussion 525-6.
Spain DA, Richardson JD, Polk HC Jr, et al. Venous thromboembolism in the high-risk trauma patient: Do risks justify aggressive screening and prophylaxis?. J Trauma. 1997 Mar;42(3):463-7; discussion 467-9.
Spannagel U, Kujath P. Low molecular weight heparin for the prevention of thromboembolism in outpatients immobilized by plaster cast. Semin Thromb Hemost. 1993;19(Suppl 1):131-41. [pmid: 8395716].
St. Anthony's complete RBRVS. Reston, VA. St. Anthony Publishing, Inc.; 1997.
Strandness DE, Langlois Y, Cramer M, et al. Long-term sequelae of acute venous thrombosis. JAMA. 1983;250:1289-92. [pmid: 6876315].
Svend-Hansen H, Bremerskov V, Gotrik J, et al. Low-dose heparin in proximal femoral fractures. Failure to prevent deep-vein thrombosis. Acta Orthop Scand. 1981 Feb;52(1):77-80.
Tartiere J, Thomassin C, Besnard M, et al. [Normovolemic hemodilution in the prevention of venous thrombosis in orthopedic and traumatologic surgery]. [Fre]. Cah Anesthesiol. 1984 Mar;32(3):203-7.
Tilsner V. [Anticoagulant-induced prophylaxis of thrombosis (author's transl)]. [Ger]. Langenbecks Arch Chir. 1977 Nov;345:353-8. [pmid: 592988].
Todd JW, Frisbie JH, Rossier AB, et al. Deep venous thrombosis in acute spinal-cord injury: A comparison of 125I fibrinogen leg scanning, impedance plethysmography and venography. Paraplegia. 1976 May;14(1):50-7.
Torngren S, Engstrom L. Deep venous thrombosis after emergency gastrointestinal operations: A pilot study. Eur J Surg. 1991 Jun-Jul;157(6-7):389-91.
Toulemonde F, Kher A, Doutremepuich C. [Difficulties of assessing postoperative pulmonary embolisms. Risks of meta-analysis from clinical trials]. [Fre]. Presse Med. 1993 Jan 2-16;22(1):28-32.
Turpie AG, Gent M, Doyle DJ, et al. An evaluation of suloctidil in the prevention of deep vein thrombosis in neurosurgical patients. Thromb Res. 1985 Jul 15;39(2):173-81.
Turpie AGG. Thrombosis prevention and treatment in spinal cord injured patients. In: Bloch RF, Basbaum M, editors. Spinal cord rehabilitation. Williams and Wilkins. Philadelphia; 1986. p. 212-40.
Tuttle-Newhall JE, Rutledge R, Hultman CS, et al. Statewide, population-based, time-series analysis of the frequency and outcome of pulmonary embolus in 318,554 trauma patients [see comments]. J Trauma. 1997 Jan;42(1):90-9.
Upchurch GR Jr, Demling RH, Davies J, et al. Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. Am Surg. 1995 Sep;61(9):749-55.
van Ooijen B. Subcutaneous heparin and postoperative wound hematomas. A prospective, double-blind, randomized study. Arch Surg. 1986;121:937-40. [pmid: 3729714].
Vara-Thorbeck R, Rosell-Pradas J. [Prevention of deep venous thrombosis in hip surgery]. [Ger]. Zentralbl Chir. 1986;111(11):633-9. [pmid: 2428187].
Velmahos GC, Nigro J, Tatevossian R, et al. Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient?. J Am Coll Surg. 1998;187(5):529-33. [pmid: 9809571].
Vrahas MS. Prophylaxis of deep vein thrombosis in trauma patients. Orthopedics. 1994 Jul;17(Suppl):21-3. [pmid: 7937385].
Waring WP, Karunas RS. Acute spinal cord injuries and the incidence of clinically occurring thromboembolic disease. Paraplegia. 1991 Jan;29(1):8-16.
Warkentin TE, Levine MN, Hirsh J, et al. Heparin-induced thrombocytopenia in patients treated with low-molecular-weight heparin or unfractionated heparin [see comments]. N Engl J Med. 1995 May 18;332(20):1330-5.
Watson N. Anti-coagulant therapy in the prevention of venous thrombosis and pulmonary embolism in the spinal-cord injury. Paraplegia. 1978 Nov;16(3):265-9. [pmid: 733308].
Wattrisse G, Lecoutre D, Dufossez F, et al. [The detection of thromboembolism in orthopedic traumatology: The value and limitations of D-dimer determination by the latex method]. [Fre]. Cah Anesthesiol. 1993;41(2):130-4. [pmid: 8504347].
Wattrisse G, Lecoutre D, Groux-Pante C. [Non controlled prospective study of the efficacy and tolerance of a low molecular weight heparin]. [Fre]. J Mal Vasc. 1991;16(4):367-71. [pmid: 1665169].
Webb LX, Rush PT, Fuller SB, et al. Greenfield filter prophylaxis of pulmonary embolism in patients undergoing surgery for acetabular fracture. J Orthop Trauma. 1992;6(2):139-45. [pmid: 1602332].
Weingarden SI. Deep venous thrombosis in spinal-cord injury. Overview of the problem. Chest. 1992;102(6):636S-639S. [pmid: 1451538].
White RH, Goulet JA, Bray TJ, et al. Deep-vein thrombosis after fracture of the pelvis: Assessment with serial Duplex-ultrasound screening. J Bone Joint Surg Am. 1990 Apr;72(4):495-500.
Wichman H, Atik M, Harkess JW. The use of dextran in the prevention of thromboembolism in patients with major fractures. Surg Forum. 1968;19:467-8. [pmid: 5718707].
Williams JW, Eikman EA, Greenberg SH, et al. Failure of low dose heparin to prevent pulmonary embolism after hip surgery or above the knee amputation. Ann Surg. 1978 Oct;188(4):468-74.
Wilson JT, Rogers FB, Wald SL, et al. Prophylactic vena cava filter insertion in patients with traumatic spinal-cord injury: Preliminary results. Neurosurgery. 1994 Aug;35(2):234-9; discussion.
Winchell RJ, Hoyt DB, Walsh JC, et al. Risk factors associated with pulmonary embolism despite routine prophylaxis: Implications for improved protection. J Trauma. 1994 Oct;37(4):600-6.
Wolf H, Welzel D, Kaiser H, et al. [Evaluation of the prevention of perioperative thromboembolism with low molecular weight heparin and dihydroergotamine. A study of the incidence of lethal pulmonary embolisms and undesired symptoms, especially the risk of vasospasm and myocardial infarction]. Arzneimittel forschung. 1988 Oct;38(10):1516-9.
Wood KB, Kos PB, Abnet JK, et al. Prevention of deep-vein thrombosis after major spinal surgery: A comparison study of external devices. J Spinal Disord. 1997 Jun;10(3):209-14.
Xabregas A, Gray L, Ham JM. Heparin prophylaxis of deep vein thrombosis in patients with a fractured neck of the femur. Med J Aust. 1978 June 3;1(11):620-2.
Zagrodnick J, Kaufner HK. [Ambulatory thromboembolism prevention in traumatology using self-injection of heparin]. [Ger]. Unfallchirurg. 1990 Jul;93(7):331-3.
Zanasi R, Fioretta G, Ciocia G, et al. Prevention of deep venous thrombosis in orthopedic surgery: Effects of defibrotide. Clin Ther. 1988;10(4):350-7. [pmid: 3079005].
Zekert F. [Thrombosis, embolism and aggregation inhibitors in surgery]. [Ger]. Fortschr Med. 1976 Nov 4;94(31):1791-8. [pmid: 1002084].
Zekert F, Kohn P, Vormittag E, et al. [Prevention of thromboembolism using acetylsalicylic acid in the surgery of hip-joint proximal fractures]. [Ger]. Monatsschr Unfallheilk Versicher Versorg Verkehrsmed. 1974 Mar;77(3):97-110.