# References

Abelseth G, Buckley RE, Pineo GE, et al. Incidence of deep-vein thrombosis in patients with fractures of the lower extremity distal to the hip. J Orthop Trauma. 1996;10(4):230-5. [pmid: 8723400].
Agnelli G, Volpato R, Radicchia S, et al. Accuracy of real-time B-mode ultrasonography in the diagnosis of asymptomatic deep-vein thrombosis in hip surgery patients. Thromb Haemost. 1991;65:1728-32.
Anglen JO, Bagby C, George R. A randomized comparison of sequential-gradient calf compression with intermittent plantar compression for prevention of venous thrombosis in orthopedic trauma patients: Preliminary results. Am J Orthop. 1998 Jan;27(1):53-8.
Barritt DW, Jordan SG. Angicoagulant drugs in the treatment of pulmonary embolism: A controlled trial. Lancet. 1960;I:1309-12.
Bergqvist D, Lindblad B. A 30-year survey of pulmonary embolism verified at autopsy: An analysis of 1274 surgical patients. Br J Surg. 1985;72:105-8. [pmid: 3971113].
Bergqvist D, Matzsch T, Burmark US, et al. Low molecular weight heparin given the evening before surgery compared with conventional low-dose heparin in prevention of thrombosis. Br J Surg. 1988;75:888-91. [pmid: 2846113].
Brach BB, Moser KM, Cedar L, et al. Venous thrombosis in acute spinal cord paralysis. J Trauma. 1977 Apr;17(4):289-92.
Brandjes DP, Heijboer H, Buller HR, et al. Acenocoumarol and heparin compared with acenocoumarol alone in the initial treatment of proximal-vein thrombosis. N Engl J Med. 1992;327:1485-9. [pmid: 1406880].
Burns GA, Cohn SM, Frumento RJ, et al. Prospective ultrasound evaluation of venous thrombosis in high-risk trauma patients. J Trauma. 1993;35:405-8. [pmid: 8371299].
Butson ARC. Intermittent pneumatic calf compression for prevention of deep venous thrombosis in general abdominal surgery. Am J Surg. 1981;142:525-7. [pmid: 7025675].
Casas ER, Sanchez MP, Arias CR, et al. Prophylaxis of venous thrombosis and pulmonary embolism in patients with acute traumatic spinal cord lesions. Paraplegia. 1977 Nov;15(3):209-14.
Clagett GP, Reisch JS. Prevention of venous thromboembolism in general surgical patients. Ann Surg. 1988;208:227-40. [pmid: 2456748]. [pmcid: 1493611].
Clagett GP, Anderson FA Jr., Geerts W, et al. Prevention of venous thromboembolism. Chest. 1998;114:531S-560S. [pmid: 9822062].
Cole CW, Shea B, Bormanis J. Ancrod as prophylaxis or treatment for thromboembolism in patients with multiple trauma. Can J Surg. 1995 Jun;38(3):249-54.
Comerota AJ, Chouhan V, Harada RN, et al. The fibrinolytic effects of intermittent pneumatic compression. Mechanism of enhanced fibrinolysis. Ann Surg. 1997;226(3):306-14. [pmid: 9339937].
Consensus Conference. Prevention of venous thrombosis and pulmonary embolism. JAMA. 1986;256:744-9. [pmid: 3723773].
Coon WM. The spectrum of pulmonary embolism. Arch Surg. 1976;111:398-402. [pmid: 1259577].
Dennis JW, Menawat S, Von Thron J, et al. Efficacy of deep venous thrombosis prophylaxis in trauma patients and identification of high-risk groups. J Trauma. 1993 Jul;35(1):132-8; discussion 138-9.
DerSimonian R, Laird NM. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7:177-88. [pmid: 3802833].
Dries DJ. Activation of the clotting system and complement after trauma. New Horizons. 1996;4:276-89. [pmid: 8774802].
Engel S, Evans SP, Mikk M, et al. D-dimer in the early diagnosis of thromboembolic disease in acute spinal injuries. Med J Aust. 1993 May 17;158(10):705-6.
Fisher CG, Blachut PA, Salvian AJ, et al. Effectiveness of pneumatic leg compression devices for the prevention of thromboembolic disease in orthopaedic trauma patients: A prospective, randomized study of compression alone versus no prophylaxis. J Orthop Trauma. 1995 Feb;9(1):1-7.
Frisbie JH, Sasahara AA. Low dose heparin prophylaxis for deep venous thrombosis in acute spinal-cord injury patients: A controlled study. Paraplegia. 1981;19(6):343-6. [pmid: 7031568].
Geerts WH, Code KI, Jay RM, et al. A prospective study of venous thromboembolism after major trauma [see comments]. N Engl J Med. 1994 Dec 15;331:1601-6.
Geerts WH, Jay RM, Code KI, et al. A comparison of low-dose heparin with low-molecular-weight heparin as prophylaxis against venous thromboembolism after major trauma [see comments]. N Engl J Med. 1996 Sep 5;335(10):701-7.
Gehling H, Giannadakis K, Lefering R, et al. [Prospective randomized pilot study of ambulatory prevention of thromboembolism. 2 times 500 mg aspirin (ASS) vs. clivarin 1750]. Unfallchirurg. 1998;101(1):42-9. [pmid: 9522671].
Gold MR, Siegel JE, Russell LB, et al. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Gosin JS, Graham AM, Ciocca RG, et al. Efficacy of prophylactic vena cava filters in high-risk trauma patients. Ann Vasc Surg. 1997 Jan;11(1):100-5.
Gottschalk A, Bisesi MA, Stein PD. Ventilation-perfusion lung scans for the diagnosis of acute pulmonary embolism. In: Hull RD, Raskob GE, Pineo GF, editors. Venous thromboembolism: An evidence-based atlas. Armonk, NY: Futura Publishing Co.; 1996.
Green D, Lee MY, Ito VY, et al. Fixed- vs adjusted-dose heparin in the prophylaxis of thromboembolism in spinal-cord injury. JAMA. 1988 Sep 2;260(9):1255-8.
Green D, Lee MY, Lim AC, et al. Prevention of thromboembolism after spinal-cord injury using low-molecular-weight heparin [see comments]. Ann Intern Med. 1990 Oct 15;113:571-4.
Green D, Rossi EC, Yao JS, et al. Deep vein thrombosis in spinal-cord injury: Effect of prophylaxis with calf compression, aspirin, and dipyridamole. Paraplegia. 1982 Aug;20(4):227-34.
Green D, Twardowski P, Wei R, et al. Fatal pulmonary embolism in spinal-cord injury. Chest. 1994 Mar;105(3):853-5.
Hachen HJ. Prevention of thromboembolism in paraplegics. [Fre]. Agressologie. 1983 Nov;24(10):527-30. [pmid: 6670682].
Haentjens P. Thromboembolic prophylaxis in orthopaedic trauma patients: A comparison between a fixed dose and an individually adjusted dose of a low molecular weight heparin (nadroparin calcium) [see comments]. Injury. 1996 Jul;27(6):385-90.
Halstuk K, Mahler D, Baker WH. Late sequelae of deep venous thrombosis: Diagnostic and therapeutic considerations. Am J Surg. 1984;147:216-20. [pmid: 6696194].
Harris S, Chen D, Green D. Enoxaparin for thromboembolism prophylaxis in spinal injury: Preliminary report on experience with 105 patients. Am J Phys Med Rehabil. 1996 Sep-Oct;75(5):326-7.
Headrick JR Jr., Barker DE, Pate LM, et al. The role of ultrasonography and inferior vena cava filter placement in high-risk trauma patients. Am Surg. 1997 Jan;63(1):1-8.
Hill SL, Berry RE, Ruiz AJ. Deep venous thrombosis in the trauma patient. Am Surg. 1994 Jun;60(6):405-8.
Hull RD, Raskob GE, Hirsh J, et al. Continuous intra-venous heparin compared with intermittent subcutaneous heparin in the initial treatment of proximal-vein thrombosis. N Engl J Med. 1986;315:1109-14. [pmid: 3531862].
Hull RD, Raskob GE, Pineo GF, editors. Venous thromboembolism: An evidence-based atlas. Armonk, NY: Futura Publishing Co.; 1996.
Hull RD, Raskob GE, Rosenbloom D, et al. Heparin for 5 days as compared with 10 days in the initial treatment of proximal venous thrombosis. N Engl J Med. 1990;327:1485-9.
Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of randomized clinical trials: Is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
Kakkar VV, Cohen AT, Edmondson RA, et al. Low molecular weight heparin versus standard heparin for prevention of venous thromboembolism after major abdominal surgery. Lancet. 1993;341:259-65. [pmid: 8093915].
Kakkar VV, Corrigan TP, Fossard DP. Prevention of fatal postoperative pulmonary embolism by low doses of heparin. An international multicentre trial. Lancet. 1975;7:45-51.
Khansarinia S, Dennis JW, Veldenz HC, et al. Prophylactic Greenfield filter placement in selected high-risk trauma patients. J Vasc Surg. 1995 Sep;22(3):231-5; discussion 235-6.
Kleinschmidt S, Seyfert UT. Heparin-induced thrombocytopenia (HAT)-Still a diagnostic and therapeutical problem in clinical practice. Angiology. 1995;46(1):37-44. [pmid: 7818155].
Knudson MM, Collins JA, Goodman SB, et al. Thromboembolism following multiple trauma. J Trauma. 1992 Jan;32(1):2-11.
Knudson MM, Lewis FR, Clinton A, et al. Prevention of venous thromboembolism in trauma patients. J Trauma. 1994 Sep;37(3):480-7.
Knudson MM, Morabito D, Paiement GD, et al. Use of low molecular weight heparin in preventing thromboembolism in trauma patients. J Trauma. 1996 Sep;41(3):446-59.
Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. Implementing ambulatory prevention of thrombosis with low molecular weight heparin in plaster immobilization of the lower extremity. [Ger]. Unfallchirurgie. 1994 Dec;20(6):319-28.
Kriemer-Nielsen H, Husted SE, Krusell LR, et al. Silent pulmonary embolism in patients with deep venous thrombosis. Incidence and fate in a randomized, controlled trial of anticoagulation versus no anticoagulation. J Intern Med. 1994;235:457-61. [pmid: 8182402].
Kudsk KA, Fabian T, Baum S, et al. Silent deep venous thrombosis in immobilized multiple trauma patients. Am J Surg. 1989 Dec;158:515-9. [pmid: 2589580].
Laird NM, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6:5-30. [pmid: 2361819].
Lensing AWA, Davidson BL, Prins MH, et al. Diagnosis of deep vein thrombosis with ultrasound imaging in symptomatic and asymptomatic high-risk patients. In: Hull RD, Raskob GE, Pineo GF, editors. Venous thromboembolism: An evidence-based atlas. Armonk, NY: Futura Publishing Co.; 1996.
Lindblad B, Eriksson A, Bergqvist D. Autopsy-verified pulmonary embolism in a surgical department: Analysis of the period from 1951 to 1988. Br J Surg. 1991;78:849-52. [pmid: 1873716].
Merli GJ, Doyle L, Crabbe S, et al. Prophylaxis for deep vein thrombosis in acute spinal-cord injury comparing two doses of low molecular weight heparinoid in combination with external pneumatic compression. J Rehabil Res Dev. 1991;28(1):434-5.
Merli GJ, Herbison GJ, Ditunno JF, et al. Deep vein thrombosis: Prophylaxis in acute spinal cord injured patients. Arch Phys Med Rehabil. 1988 Sep;69(9):661-4.
Meyer CS, Blebea J, Davis K Jr., et al. Surveillance venous scans for deep venous thrombosis in multiple trauma patients. Ann Vasc Surg. 1995 Jan;9(1):109-14.
Moher D, Jadad AR, Klassen TP. Does quality of reports of randomized trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
Morris GK, Mitchell JRA. Warfarin sodium in prevention of deep venous thrombosis and pulmonary embolism in patients with fractured neck of the femur. Lancet. 1976;ii:869-72.
Napolitano LM, Garlapati VS, Heard SO, et al. Asymptomatic deep venous thrombosis in the trauma patient: Is an aggressive screening protocol justified?. J Trauma. 1995 Oct;39(4):651-7; discussion 657-9.
Nicolaides AN. Small doses of subcutaneous sodium heparin in preventing deep thrombosis after major surgery. Lancet. 1972;2:890-3. [pmid: 4116600].
Nicolaides AN, Miles C, Hoare M, et al. Intermittent sequential pneumatic compression of the legs and thromboembolism-deterrent stockings in the prevention of postoperative deep venous thrombosis. Surgery. 1983;94(1):21-5. [pmid: 6857507].
Normand R, Mathieu JP. Prevention of venous thromboses under plaster casts after leg injury. Comparison of heparin-calcium and pentosan sulfuric polyester. [Fre]. Cah Anesthesiol. 1987 Nov;35(7):559-62.
Pachter HL, Riles TS. Low dose heparin: Bleeding and wound complications in the surgical patient. A prospective randomized study. Ann Surg. 1977;186(6):669-74. [pmid: 603271].
PIOPED Investigators. Value of the ventilation/perfusion scan in acute pulmonary embolism-results of the prospective investigation of pulmonary embolism diagnosis (PIOPED). JAMA. 1990;263:2753-9. [pmid: 2332918].
Piotrowski JJ, Alexander JJ, Brandt CP, et al. Is deep vein thrombosis surveillance warranted in high-risk trauma patients?. Am J Surg. 1996 Aug;172(2):210-3.
Rodriguez JL, Lopez JM, Proctor MC, et al. Early placement of prophylactic vena caval filters in injured patients at high risk for pulmonary embolism. J Trauma. 1996 May;40(5):797-802; discussion 802-4.
Rogers FB, Shackford SR, Ricci MA, et al. Prophylactic vena cava filter insertion in selected high-risk orthopaedic trauma patients. J Orthop Trauma. 1997 May;11(4):267-72.
Rogers FB, Strindberg G, Shackford SR, et al. Five-year follow-up of prophylactic vena cava filters in high-risk trauma patients. Arch Surg. 1998 Apr;133(4):406-11; discussion 412.
Ruiz AJ, Hill SL, Berry RE. Heparin, deep venous thrombosis, and trauma patients [see comments]. Am J Surg. 1991 Aug;162(2):159-62.
Sackett DL. How to read clinical journals: I-V. Can Med Assoc J. 1981;124:695-750.
St. Anthony's complete RBRVS. Reston, VA: St. Anthony Publishing, Inc.; 1997.
Salzman EW, Harris WH, DeSanctis RW. Anticoagulation for prevention of thromboembolism following fractures of the hip. N Engl J Med. 1966 (July 21);275(3):122-30.
Schott G, Elsel W, Mockel G, et al. Prevention of thromboembolism with heparin and dihydroergotamine in a trauma surgery patient sample-comparison of the effectiveness of different administration forms of dihydroergotamine. [Ger]. Z Arztl Fortbild. 1992 Oct 12;86(19):973-6.
Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias: Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
Silverstein MD, Heit JA, Mohr DN, et al. Trends in the incidence of deep venous thrombosis and pulmonary embolism. A 25-year population-based study. Arch Intern Med. 1998;158:585-93. [pmid: 9521222].
Smith EB. Pulmonary embolism-A concept for survival. J Natl Med Assoc. 1991 Mar;83(3):255-7. [pmid: 2038086].
Spain DA, Richardson JD, Polk HC Jr., et al. Venous thromboembolism in the high-risk trauma patient: Do risks justify aggressive screening and prophylaxis?. J Trauma. 1997 Mar;42(3):463-7; discussion 467-9.
Spannagel U, Kujath P. Low molecular weight heparin for the prevention of thromboembolism in outpatients immobilized by plaster cast. Semin Thromb Hemost. 1993;19(Suppl 1):131-41. [pmid: 8395716].
Strandness DE, Langlois Y, Cramer M, et al. Long-term sequelae of acute venous thrombosis. JAMA. 1983;250:1289-92. [pmid: 6876315].
Todd JW, Frisbie JH, Rossier AB, et al. Deep venous thrombosis in acute spinal-cord injury: A comparison of 125I fibrinogen leg scanning, impedance plethysmography and venography. Paraplegia. 1976 May;14(1):50-7.
Turpie AG, Gent M, Doyle DJ, et al. An evaluation of suloctidil in the prevention of deep vein thrombosis in neurosurgical patients. Thromb Res. 1985 Jul 15;39(2):173-81.
Turpie AGG. Thrombosis prevention and treatment in spinal cord injured patients. In: Bloch RF, Basbaum M, editors. Spinal cord rehabilitation. Philadelphia: Williams and Wilkins; 1986. p. 212-40.
Upchurch GR Jr., Demling RH, Davies J, et al. Efficacy of subcutaneous heparin in prevention of venous thromboembolic events in trauma patients. Am Surg. 1995 Sep;61(9):749-55.
van Ooijen B. Subcutaneous heparin and postoperative wound hematomas. A prospective, double-blind, randomized study. Arch Surg. 1986;121:937-40. [pmid: 3729714].
Velmahos GC, Nigro J, Tatevossian R, et al. Inability of an aggressive policy of thromboprophylaxis to prevent deep venous thrombosis (DVT) in critically injured patients: Are current methods of DVT prophylaxis insufficient?. J Am Coll Surg. 1998;187(5):529-33. [pmid: 9809571].
Waring WP, Karunas RS. Acute spinal cord injuries and the incidence of clinically occurring thromboembolic disease. Paraplegia. 1991 Jan;29(1):8-16.
Webb LX, Rush PT, Fuller SB, et al. Greenfield filter prophylaxis of pulmonary embolism in patients undergoing surgery for acetabular fracture. J Orthop Trauma. 1992;6(2):139-45. [pmid: 1602332].
Weingarden SI. Deep venous thrombosis in spinal-cord injury. Overview of the problem. Chest. 1992;102(6):636S-639S. [pmid: 1451538].
Wilson JT, Rogers FB, Wald SL, et al. Prophylactic vena cava filter insertion in patients with traumatic spinal-cord injury: Preliminary results. Neurosurgery. 1994 Aug;35(2):234-9; discussion.
Winchell RJ, Hoyt DB, Walsh JC, et al. Risk factors associated with pulmonary embolism despite routine prophylaxis: Implications for improved protection. J Trauma. 1994 Oct;37(4):600-6.