# Future Research

There are significant gaps in the scientific literature in the field of prevention of VT after trauma, especially regarding the methods of prophylaxis or screening and the uniform description of patients.

## Methods of Screening

The best method of screening is probably the most difficult issue to resolve. A study comparing the most convenient method for screening (Duplex ultrasonography) with the current gold standard for diagnosis of DVT (ascending venography) would yield valuable conclusions. Results from such a study could make physicians aware of the limitations of Duplex ultrasound in critically ill patients and alert them to the possibility of missing a DVT diagnosis, with catastrophic consequences, resulting from reliance on Duplex results. Alternatively, such results could indicate that Duplex is sensitive and specific, even for edematous, severely injured patients. Even with its limitations, Duplex ultrasonography may still remain the screening method of choice in most centers because it is convenient, noninvasive, inexpensive, and repeatable, and it can be done at the bedside. D-dimers is a promising new test that still needs to be explored.

Other methods of screening such as radiolabeled fibrinogen scanning or impedance plethysmography have not been adopted by most trauma centers and should probably not be studied further. We believe that further studies to identify the best method of screening should not be the highest priority at this time.

## Selection of Appropriate Patients for VT Prophylaxis

### Identification of the Best Method of Prophylaxis

Our evidence report shows that high-quality data for these two very important topics is scanty, and firm conclusions cannot be drawn, despite the common belief that the answers exist in the literature. Although numerous studies could be designed around these topics, ideally one large multicenter trial should answer the major relevant questions. This study must do the following:

- Involve multiple trauma centers with high volumes of trauma patients and expertise in this particular field.
- Have a randomized, controlled design to help insure equivalence among groups at baseline.
- Define appropriate inclusion criteria for "trauma" patients.
- Compare the most important (and most commonly used) methods of prophylaxis (i.e., LMWH, LDH, and SCDs).
- Adopt a strict screening protocol for DVT, regardless of symptoms, and a flexible protocol for investigating pulmonary embolism in the presence of symptoms.
- Accumulate numbers that can provide statistical significance based on careful power analysis.
- Analyze this large sample of patients to identify risk factors for VT.

Some physicians may consider the inclusion of a no-prophylaxis group to be unethical at this point. However, in this evidence report the limited amount of reliable data generated the conclusion that conventional methods of prophylaxis do not offer any proven advantage over no prophylaxis. A panel of experts should decide if a no-prophylaxis group should be included in the multicenter trial that we propose. Based on the available data, the efficacy of prophylactic therapy in preventing DVT in trauma patients is in sufficient doubt to justify the use of a no-prophylaxis group in clinical trials.

We estimated the sample sizes that would be needed for a large, randomized, controlled trial to demonstrate statistically significant reductions in DVT rates (Table 56). The power analysis assumed an -error of 0.05 and a power of 80 percent, 90 percent, or 95 percent. We estimated sample sizes according to two different scenarios:

1 A reduction in the incidence of DVT from 11.8 percent (the general incidence in all trauma patients, as found in our analysis) to 9 percent (the incidence that would make the most expensive method of prophylaxis, LMWH, cost-effective for a person of the average age of the trauma population: 30--35 years old, see Tables 54-55).
2 A reduction in the incidence of DVT from 11.8 percent to 6 percent (a 50 percent reduction, which is a clinically significant endpoint).

Table 56. Power analysis to estimate the number of patients required to achieve reduction in DVT rates^1^

Test significance level, α | 0.050 | 0.050 | 0.050 | 0.050 | 0.050 | 0.050
Group 1 proportion, π _1_ | 0.118 | 0.118 | 0.118 | 0.118 | 0.118 | 0.118
Group 2 proportion, π _2_ | 0.090 | 0.090 | 0.090 | 0.060 | 0.060 | 0.060
Odds ratio, ψ= π _2_ (1-π _1_)/[ π _1_ (1-π _2_)] | 0.739 | 0.739 | 0.739 | 0.477 | 0.477 | 0.477
Power (%) | 80 | 90 | 95 | 80 | 90 | 95
n per group | 1,936 | 2,567 | 3,158 | 411 | 539 | 658

1Two-groups continuity-corrected chi-squared test of equal proportions.

DVT, deep venous thrombosis.

According to different power estimates and reduction rates, the sample sizes range from 411 to 3,158 patients per group. For example, to reduce the incidence of DVT with LMWH from 11.8 percent to 9 percent in a statistically significant way, assuming a power of 80 percent, approximately 4,000 patients should be included (2,000 in each group). This sample size alone strongly indicates the necessity of a multicenter trial.

## The Role of Vena Cava Filters

The issue of VCFs is extremely important, and further research should be definitely done in this direction. We propose two study methodologies on this topic:

- Including this question in the multicenter trial: Patients should be stratified to those who could receive other methods of prophylaxis and those who had contraindications to other methods or had lifelong risk for VT. These latter patients should be randomized to receive or not receive a VCF.
- Designing a different study, specifically to answer this question: In such a study, all patients who were deemed to be at high risk for DVT according to predefined criteria should be randomized to receive or not receive a VCF, regardless of other methods of prophylaxis given simultaneously.

Both studies should have a predetermined protocol for evaluating PE according to symptoms, an aggressive autopsy policy to examine for PE and its possible association with death, and careful short-term and long-term followup to detect complications related to VCF.