# Conclusions

This evidence report evaluated the trauma literature to answer specific questions relevant to the prevention of VT after injury. Most of the published data in this field are of low quality, and much of the information comes from noncontrolled trials. To date, policies and methods of management and policies have been based on extrapolation of conclusions from different types of patients to the trauma population. However, trauma patients constitute an entirely different population from cancer, elderly, or elective-surgery patients. In addition, trauma is followed by significant acute physiologic changes that influence the response of injured patients to different treatment methods.

Following the technical experts' recommendation, the project staff decided to adopt a strict approach and avoid including in the analysis any articles that did not address trauma patients. Defining "trauma" for the purposes of this project was difficult. The panel believed that elderly patients with minimal mechanism of injury and burn patients should be excluded because they represented different patient populations than the trauma patients for whom we targeted the evidence report. All other studies that included only trauma patients or mixed populations and provided separate data for trauma patients were included.

We included papers dealing with nonelderly patients with minimal injuries in the analysis only because they were few (four), of good quality (all RCTs), and referred to a specific population (patients with lower-extremity injuries). Stratification of our database according to types of population allowed us to analyze these patients separately.

## What Is the Incidence of DVT and PE?

### Incidence of DVT

DVT was easier to measure as an outcome and had better quality data than the available data on PE. Although DVT rates varied according to the method, frequency, and duration of screening, the pooled incidence in all studies was 11.8 percent. A higher incidence should be expected in patients with specific risk factors such as spinal fractures, spinal cord injuries, or older age or after careful screening of the extremity veins. However, 12 percent can be used as a target number in the design of future research testing different methods of prophylaxis.

We avoided distinguishing between proximal and distal DVT for two reasons. First, many studies did not report on them separately. Second, it is still not clear whether only proximal DVT is clinically significant, or whether distal DVT could also be life-threatening by producing PE. Certainly, the latter problem becomes particularly important after the alarmingly high incidence of PE in the absence of documented proximal DVT (Coon, 1976; Velmahos, Nigro, Tatevossian, et al., 1998).

### Incidence of PE

Determining the incidence of PE from the trauma literature proved to be a much more difficult task. Essentially no studies used routine screening for PE, and all investigators relied on clinical symptoms before initiating therapy or further investigation. However, the clinical symptomatology of PE is notoriously unreliable, and the signs associated with this disease become more vague in an intensive care unit (ICU) environment. Therefore, the incidence of PE provided by our analysis should be viewed with caution. According to the pooled data, the overall incidence of PE is 1.5 percent and varies, according to the type of trauma or study methodology, from 0.1 percent to 15 percent.

## What Is the Best Method of Preventing VT?

Firm conclusions as to the best method of preventing VT cannot be made based on the available literature data. The randomized clinical trials that have been published are usually unique (i.e., only one type of comparison has ever been published), frequently of low methodologic quality, and clinically heterogeneous. We assessed both clinical trial data and observational data, but our results remained consistent. We were unable to demonstrate any benefit of one method over another in preventing VT. However, we note that the confidence intervals in our pooled results are wide, in some instances very wide, and we therefore cannot exclude a clinically important effect. For example, many of our odds ratios have confidence intervals that include 2, which for these low-frequency events approximates the risk ratio. A prophylactic method with a risk ratio of 2 in its favor would be associated with one-half as many episodes of DVT or PE-a clinically important result. The existing limited data do not allow us to exclude a benefit of this magnitude for most of these prophylactic methods.

We compared three methods in our primary meta-analysis: LDH, SCDs, and no prophylaxis. The outcome parameter was DVT. There was no difference in DVT rates after administration of LDH or application of SCD. Even more surprising, there was no difference in DVT rates between LDH or SCD and no prophylaxis. This may be because of the small number of patients included in each study, the methodologic flaws of the studies, or the real absence of a difference. We compared a fourth method (LMWH) against LDH in a combined RCT/non-RCT meta-analysis with PE as the outcome parameter. This comparison showed no difference in PE prevention.

LMWH is a new and promising pharmacologic agent for VT prophylaxis. We hoped that we could compare its safety and efficacy against other methods of prophylaxis by meta-analysis. Unfortunately, we identified only two RCTs (Geerts, Jay, Code, et al., 1996; Knudson, Morabito, Paiement, et al., 1996) comparing LMWH against LDH or SCD. Both studies are of high quality and show an outcome benefit in favor of LMWH. However, they are heterogeneous: One study (Geerts, Jay, Code, et al., 1996) reported DVT rates of 31 percent and 44 percent according to the use of LMWH or LDH, respectively, whereas the other (Knudson, Morabito, Paiement, et al., 1996) reported DVT rates of 0.8 percent and 2.4 percent when LMWH or SCD are used respectively. The sample sizes were too small to make any conclusion on comparisons on these drugs' safety. These widely different DVT rates between the two studies could be because of different study methodologies (particularly in the methods of DVT diagnosis) or different populations examined, which may make the interpretation of their results difficult. In the absence of at least three RCTs, meta-analysis could not be performed on this topic.

Our analysis of the limited reliable literature data leads us to conclude that LDH or SCD offer no proven advantage over each other or over no prophylaxis for the prevention of DVT after trauma.

## What Are the Risk Factors for VT?

Multiple risk factors have been reported for the development of VT. Our analysis focused on risk factors included in at least three studies. The risk factors were examined as continuous or categorical (dichotomous) values according to how they were reported in their respective articles.

Of the categorical risk factors examined (gender, head injuries, spinal fractures, spinal cord injuries, long-bone fractures, and pelvic fractures), only spinal fractures and spinal cord injuries were found on pooled analysis to affect the incidence of VT. The presence of spinal fractures or spinal cord injures increases the odds for development of DVT twofold and threefold, respectively, relative to patients without spinal trauma. We were unable to confirm that widely published risk factors, such as pelvic fractures, long-bone fractures, or head injuries, affect the incidence of VT. A possible explanation for this outcome is that the studies we analyzed included multiple trauma patients who were already at the highest risk of VT. In such patients, individual risk factors may not increase an already high risk any further.

Of the continuous variables we examined (age, Injury Severity Score [ISS], blood transfusion), age and ISS were significantly different between patients with and without VT. Patients with DVT were on average 9 years older and had an ISS that was 1.5 points higher than that of patients without DVT. The ISS difference, however, has limited clinical significance. There were insufficient data to identify threshold figures of age or ISS above which VT rates increased significantly.

We conclude that the presence of spinal fractures or spinal cord injuries is a significant risk factor for the development of VT. The likelihood of developing VT increases with age and ISS, but the threshold at which the rate of increase changes significantly cannot be determined.

## What Is the Role of Vena Cava Filters in Preventing PE?

The data we analyzed on the role of vena cava filters (VCFs) were derived from methodologically poor studies: no RCT in the trauma literature addressed the role of VCF. From the existing literature, it seems that VCF decreases the risk of PE and fatal PE in severely injured patients. The absence of severe complications associated with VCF use in the studies that we examined suggests that this device is safe. However, firm conclusions on its short-term and long-term safety cannot be made from the available data.

Most authorities would agree that a mechanical interruption to the flow of blood clots from the systemic veins to the pulmonary circulation is an effective method for preventing this complication. However, defining the appropriate trauma population for VCF placement remains difficult. The physician needs to balance the risk of PE with the risk of placing a device that will remain in the bloodstream for life in a (typically) young trauma patient. We cannot draw conclusions as to the role of VCF in the prevention of VT after trauma on the basis of the existing data.

## Cost-Effectiveness

Because the meta-analysis showed no differences in VT rates in patients treated by different methods of prophylaxis vs. no prophylaxis, the cost-effectiveness of prophylaxis cannot be established. All methods of prophylaxis will be associated with the cost of the drug or device used and the possible complications of its use. Therefore, because there is no proof that the risk of VT is not decreased by any method of prophylaxis, no prophylaxis will be more cost-effective than any other approach. However, the small sample sizes used in our meta-analysis and the wide 95 percent confidence intervals of most calculated odds ratios indicate that differences among different methods of prophylaxis may reveal themselves if appropriate numbers of patients are evaluated. For this reason, we proceeded to estimate the cost per year-life saved according to different probabilities of DVT occurrence. Our results showed that prophylaxis for DVT may be cost-effective (using accepted limitations) at rates of efficacy within the 95% confidence intervals of our estimates.

In this analysis, we estimated the cost of each of the three most commonly used methods of prophylaxis (LDH, LMWH, mechanical) that would save 1 year of a person's life over the estimated life span according to his/her age by decreasing the incidence of DVT (and eventual PE). This information will be very useful when future research on this topic attempts to use power analysis to identify the sample sizes required to prove that a certain method is cost-effective.

The figure of approximately $50,000 per life-year saved is used as the upper limit to determine cost-effectiveness for each method or drug investigated. The entire cost of a method used is divided by the estimated years that a person may live, yielding the cost per life-year saved. Therefore, the cost per life-year saved will be lower for a young person than for an older person for a therapy that has the same cost (entire cost of therapy will be divided by more years of projected life). So, a method becomes more cost-effective the younger a person is.

Because LDH is identified as the least expensive method for VT prevention of the three examined, it will be more cost-effective than the other methods because no method is superior in preventing VT. If future studies show that another method of prophylaxis is more effective than LDH, the cost-effectiveness results will change. We believe that the information provided in this analysis will help design future studies on this topic.

## Limitations

The primary limitation of the current evidence report is the quantity and quality of original studies. Only a few RCTs were identified, and approximately one-half of thesecould not be combined for meta-analysis. Most of our meta-analyses addressing methods of prophylaxis used only three or four studies with a low total number of patients. For this reason, we added non-RCTs to RCTs in order to increase the sample size. Although such a meta-analytic design is inherently weaker, it was consistent with the results of the meta-analysis of RCTs. The absence of a proven benefit for different methods of prophylaxis of VT was found after meta-analysis of RCTs as well as RCTs and non-RCTs together.

The majority of controlled or noncontrolled trials scored one-half or lower of the highest possible score on our quality scoring scale. Because we had so few RCTs for meta-analysis, we could not exclude studies that were of low quality. We also made no attempt to give greater importance to studies that had better design and, therefore, presumably more valid results. This was because, in general, there is a lack of empirical evidence relating study design to bias.

The way we defined "trauma patients" could be viewed as an additional limitation. After careful consideration by the technical expert panel, the definition excluded burn patients and elderly patients with minimal mechanism of injury. However, we believe that this definition limits this report to the population intended to be studied.

Finally, the heterogeneity of studies, as shown by the respective statistical tests, may have influenced some of the results. Surprisingly, the tests did not indicate significant heterogeneity for most comparisons. However, the trauma populations that were combined to perform meta-analysis (e.g., spinal-cord injuries with general trauma) were not always similar. These groups of patients have individual characteristics and risk factors for VT. Combining them could be inappropriate in some cases from a pathophysiologic point of view. Again, the limited number of available studies provided little opportunity to isolate these groups for individual study.