# Methodology

## Scope of Work

Shortly after project assignment to the Southern California Evidence-based Practice Center, and following two preliminary meetings (October 1 and 5, 1998) among the core project staff, the University of Southern California (USC)/RAND team met (October 9, 1998) to define the scope of work, discuss pertinent issues, form a general plan, and solve problems. Project staff outlined the scope of work, which included the following:

- Identification of technical experts to be primary advisors throughout the project.
- Selection of important questions relevant to the topic.
- Design of an exhaustive literature search for English and foreign-language articles, as well as abstracts or possibly unpublished work.
- Extraction of data from selected articles as the search progressed to increasingly relevant materials, and continuous data entry into a special computer database.
- Synthesis of evidence and supplemental analysis, if needed.
- Development and dissemination of an evidence-based report.

## Design of Technical Experts Panel

We decided that the technical experts panel would be chosen from well-known authorities on VT prevention, including academic trauma surgeons, representatives of managed care and private-sector health entities, and nonsurgeons. To further cooperation with the partner organization, Eastern Association for the Surgery of Trauma (EAST), several members of EAST would be included as well. We also decided to invite several prominent members of the American Association for the Surgery of Trauma (AAST) and Western Trauma Association (WTA) to participate. These associations are the primary entities that will develop and implement guidelines based on the project report. Table 1 lists the panel of technical experts, and Table 2 lists the peer reviewers for the project report.

Table 1. Technical experts panel

Thomas V. Berne, MD | Professor of Surgery and Vice-Chairman University of Southern California, Los Angeles, CA AAST
Edward E. Cornwell III, MD | Assoc. Professor of Surgery and Director of Trauma Service Johns Hopkins University, Baltimore, MD AAST, EAST
Demetrios Demetriades, MD, PhD | Professor of Surgery and Director of Division of Trauma and Critical Care University of Southern California, Los Angeles, CA AAST
Richard Dorazio, MD | Chief of Vascular Surgery Kaiser Permanente Los Angeles, Los Angeles, CA
Timothy Fabian, MD | Professor of Surgery and Chief of Trauma Service University of Tennessee Center for the Health Sciences, Memphis, TN AAST, EAST (President)
Lazar Greenfield, MD | Professor and Chairman of Surgery University of Michigan, Ann Arbor, MI AAST
M. Margaret Knudson, MD | Associate Professor of Surgery University of California, San Francisco, CA AAST, WTA
Kenneth Mattox, MD | Professor of Surgery and Vice-Chairman, Chief of Trauma Surgery Baylor College of Medicine, Houston, TX AAST
William McGehee, MD | Associate Professor of Medicine, Department of Hematology Chief, Anticoagulation Division University of Southern California, Los Angeles, CA
Michael Pasquale, MD | Assistant Professor of Surgery Pennsylvania State University, Allentown, PA AAST; Chairman, Ad Hoc Committee on Practice Management Guideline Development, EAST
J. David Richardson, MD | Professor of Surgery and Vice-Chairman University of Louisville, Louisville, KY AAST (President)
Frederick Rogers, MD | Associate Professor of Surgery University of Vermont College of Medicine, Burlington, VT AAST; EAST: Chairman, Task Force on Deep Vein Thrombosis (1996)
C. William Schwab, MD | Professor of Surgery and Chief, Division of Traumatology and Surgical Critical Care University of Pennsylvania, Philadelphia, PA AAST, EAST
Steven R. Shackford, MD | Professor and Chairman of Surgery University of Vermont, Burlington, VT AAST, EAST, WTA (Vice President)
Kenneth Waxman, MD | Trauma Director Santa Barbara Cottage Hospital, Santa Barbara, CA AAST
Albert Yellin, MD | Professor of Surgery USC School of Medicine, Los Angeles, CA AAST, American Venous Forum, Society for Vascular Surgery

AAST, American Association for the Surgery of Trauma; EAST, Eastern Association for the Surgery of Trauma; WTA, Western Trauma Association; USC, University of Southern California

Table 2. Peer reviewers

I. Elaine Allen, Ph.D. | Associate Professor of Statistics Babson College, Wellesley, MA
Howard Belzberg, MD | Assistant Professor of Surgery USC School of Medicine, Los Angeles, CA
H. Gill Cryer, MD | Professor of Surgery University of California, Los Angeles, CA
Donald Gaspard, MD | Director of Trauma Services Huntington Memorial Hospital, Pasadena, CA
Prof. William J. Gillespie | Dean, Dunedin School of Medicine University of Otago, Dunedin, New Zealand
Lazar Greenfield, MD | Professor and Chairman of Surgery University of Michigan, Ann Arbor, MI
David Hoyt, MD | Professor and Vice Chairman of Surgery University of California, San Diego, CA
John T. Owings, MD | Assistant Professor of Surgery University of California, Davis, Sacramento, CA
Basil A. Pruitt, Jr., MD | Professor of Surgery University of Texas Health Sciences Center, San Antonio, TX
William C. Shoemaker, MD | Professor of Surgery and Anesthesiology USC School of Medicine, Los Angeles, CA
All technical experts

USC, University of Southern California

After a preliminary phone call, formal letters of invitation to participate in the panel were sent to all the technical experts. All accepted the invitation, and a conference call was scheduled to outline the scope, goals, and methodology of the project. A preparatory face-to-face meeting was arranged with several attendees at the Annual Congress of the American College of Surgeons in Orlando, Florida. Most of those who did not attend this meeting were briefed in advance by telephone and in person.

We did not find any patient advocacy groups because of the nature of the population studied. Finding representative patients for the panel would be extremely difficult, because followup on trauma patients is notoriously unreliable once they leave the hospital. Identifying patients who could represent the entire trauma population that suffered from VT was not deemed feasible or essential.

## Design of the Study

The time and resources of the project dictated that we could address three to five questions. We decided that a preliminary literature search would sample the existing evidence and suggest important questions that the evidence could answer. After defining these questions, we would submit them to the technical experts for ranking in order of importance. From the rankings we would select the three to five questions to be used for this project.

We also discussed the design of the database and the literature search and the allocation of responsibilities to the various members of the team. We decided to use separate quality screens to evaluate randomized and nonrandomized trials. A project member designed a novel, user-friendly computerized database that could easily be customized to different project needs. The foregoing issues were also discussed in a subsequent conference call (October 13) among the Task Order Officer (TOO), Center Director, and Task Order Manager. The TOO approved the plan of action developed during the meeting of the USC/RAND group.

## Process of Selecting Variables to Be Studied

The staff held its first conference call to establish the role of the technical expert panel, discuss the methodology to be followed, identify the most important questions, and define clinically relevant outcomes. After the Task Order Manager and the Center Director gave a short history and background of the project, we discussed the following issues: defining "trauma patients" and selecting the questions to be asked, the studies to be used, and the relevant outcomes.

### Defining "Trauma Patients"

The first issue discussed was the definition of the "trauma patient." The word "trauma" has been used in the literature quite liberally. It has denoted patients with severe injuries and patients with minor injuries. It has been frequently used, particularly in the orthopedic literature, to include elderly patients with hip fractures after ground-level falls, a population the technical experts did not want to include. There is abundant evidence in the literature on VT after hip fractures and elective or semielective operations for this injury, including multiple meta-analyses.

The technical experts agreed that this project should only address patients with a significant mechanism of injury, rather than a localized injury. As previously described, the pathogenesis of VT after trauma includes the activation of the inflammatory cascade with resulting abnormalities of the coagulation mechanisms. These systemic changes cause complications beyond the localized injury. The energy absorbed during the impact of trauma plays a significant role in this process. In the absence of a significant mechanism of injury, VT develops only as a result of the localized injury.

The experts recommended that we screen all articles referring to "trauma patients." Articles referring exclusively to elderly patients with orthopedic fractures after minor mechanisms of injury (e.g., ground-level fall) should be excluded. Articles referring to mixed populations (including elderly orthopedic trauma patients with minor mechanisms and non-elderly trauma patients, or patients with orthopedic trauma and patients after elective orthopedic surgery) should be included only if separate information could be found on the trauma patients; otherwise, the article should be excluded. Articles referring to non-elderly patients who had minor trauma should be included but analyzed separately from the rest of the trauma population. The panel agreed to define as "elderly" an age of more than 65 years. Studies that referred to trauma in general, orthopedic trauma, or neurosurgical trauma would be included. For example, if a study included patients with hip fractures and a mean age of 72 years old, it would be excluded. A study of patients with pelvic fractures after motor vehicle accidents or falls from a height would be included. A study of patients with pelvic fractures and patients after elective hip replacement that did not provide separate information about the two different populations would be excluded. A study of patients with spinal cord injuries and patients after elective neurosurgical operations for spinal cord tumors that provided information on demographics, treatment, and outcomes separately for the two groups would be included, but only the data for the trauma patients would be used.

### Selecting the Questions

Following the preliminary literature review, the core project staff developed seven possible questions to be studied (Table 3). These questions were circulated and approved by the entire USC/RAND team and then were faxed to the technical experts. We asked the experts to select the five most important questions and rank them in order of importance. Table 4 presents the outcome of the ranking process. The Kendall's tau coefficient of concordance was used to measure how closely the experts agreed on the ranking of questions (0.21). Friedman's test statistic was used to measure the significance of the agreement vs. no agreement (p=0.002), which indicates that there was satisfactory agreement among the experts on the relative importance of the different questions.

Table 3. Initial set of questions sent to technical experts

1. Are all injured patients at the same risk for developing venous thromboembolism? How can subgroups at high risk be identified?; 2. Do deep venous thrombotic events at various sites pose similar risks for pulmonary embolism (above the knee vs. below the knee, upper extremities vs. lower extremities)?; 3. Is surveillance for deep venous thrombosis justified? If yes, in which subgroups of trauma patients?; 4. Which is the best (safest, most accurate, most cost-effective) method of screening for deep venous thrombosis?; 5. Which is the best (safest, most accurate, most cost-effective) method for prevention of venous thromboembolism? Are combination methods better than isolated methods?; 6. Which injured patients should receive an inferior vena cava filter prophylactically?; 7. What are the contraindications for the use of prophylactic doses of standard or low-molecular-weight heparin?

Table 4. Outcome of ranking of initial seven questions

Expert | Question A | Question B | Question C | Question D | Question E | Question F | Question G
A | 2 | | 4 | 3 | 5 | 1
B | 4 | 2 | | 3 | 5 | | 1
C | 4 | | 2 | | 5 | 3 | 1
D | 1 | 2 | 3 | 4 | 5
E | 5 | 2 | 1 | | 4 | 3
F | 4 | 2 | | 1 | 5 | 3
G | | | 3 | 4 | 1 | 2 | 5
H | 1 | 5 | | 4 | 2 | | 3
I | 1 | | 3 | 4 | 5 | | 2
J | 1 | 2 | 3 | 4 | | 5
K | 2 | | | 1 | 5 | 4 | 3
L | 5 | 3 | 2 | 1 | 4
M | 1 | | 3 | | 5 | 2 | 4
N | 5 | 3 | 2 | 1 | 4
O | 1 | | 2 | | 5 | 3 | 4
P | 5 | | 3 | 4 | 1 | | 2
Q | 4 | | | 3 | 5 | 2 | 1
TOTAL | 46 | 21 | 31 | 37 | 66 | 28 | 26

Note: The technical experts were asked to rank the five most important questions with a score of 5 (most important) to 1 (least important).

All the participants had already received a copy of the first ranking of the questions. In the first round, the experts agreed that the question, "hich is the best method for prevention of VT? Are combination methods better than isolated methods?" (see Table 3) was the most important one and that the question, "Are all injured patients at the same risk for developing VT? How can subgroups at high risk be identified?" (see Table 3) was the second most important one.

The preliminary literature search, however, had yielded very few well-designed studies that addressed these questions. For example, only four randomized controlled trials with trauma patients were initially found to address the most important question, a comparison of the different methods of VT prophylaxis. A proposal was offered to include studies from the orthopedic literature and extrapolate the results to the trauma population. The panel decided to reject this idea and study only trauma patients to ensure clinical homogeneity and avoid arbitrary extrapolations resulting from analysis of mixed populations.

The question on identifying the best methods of screening (see Table 3) was also debated. Some members of the panel thought that the question was obsolete. Even if venography proved to be more sensitive and specific than Duplex ultrasound, the latter would still be the preferred method of screening of critically injured patients for reasons of convenience and safety. However, other experts believed that evaluating studies comparing Duplex ultrasound with other methods would be important. Finally, the panel decided to investigate the literature on this question, which was ranked third in order of importance, and to decide whether to report on the evidence based on the amount and quality of the existing literature.

### Selecting the Studies

The quality of published studies was discussed. The experts had different opinions as to the level of quality that should be used for this report. Because of the apparent scarcity of high-quality studies, the panel decided to include differentlevels of quality and accept that the results might have varying levels of scientific validity, as long as this was explicitly stated.

### Selecting Relevant Outcomes

The technical experts recommended unanimously that only studies with the following outcomes be included: DVT (total), DVT (proximal), PE, death from PE, bleeding related to methods of VT prevention, thrombocytopenia related to methods of VT prevention, and postphlebitic syndrome. Other complications of preventive methods, such as allergic reactions to heparin, VCF malposition or migration, or VT or caval obstruction at the filter insertion site, were thought to be important outcomes, but the information from the literature was expected to be sparse. However, we decided to record and report these events.

## Refining the Questions: Defining Causal Pathways for the Selected Questions

Following the technical experts' recommendations, the project staff consolidated the five most important questions into four. These questions were then refined (Table 5) and approved by the TOO.

Table 5. Four refined key questions for ranking with issues involved

1 What is the role of different chemical or mechanical methods in preventing venous thromboembolism?; - Which is the best (most efficient, safe and cost-effective) method to prevent venous thromboembolism?; - Are combination methods better than isolated methods?; - What are the contraindications to using each method, and what are the best alternatives when contraindications exist?; 2 What are the factors placing trauma patients at high risk for venous thromboembolism?; - Are all injured patients at the same risk for venous thromboembolism?; - What is an acceptably low rate of venous thromboembolism to recommend that there is no need for screening and thromboprophylaxis?; - How can subgroups at high risk for venous thromboembolism be identified?; 3 Which is the optimal method to screen for deep venous thrombosis?; - Which is the best (safest, most accurate, most cost-effective) method for deep venous thrombosis surveillance?; - Which groups should be screened?; - Should different groups be screened by different methods?; - How soon, how often, and for how long should screening be done?; 4 What is the role of vena cava filters in preventing pulmonary embolism?; - Which groups need a prophylactic vena cava filter?; - What is the risk for pulmonary embolism and death from deep venous thrombosis in these groups, and to what extent do vena cava filters decrease this risk?; - How safe are vena cava filters?

The four key questions were again faxed to the technical experts for re-ranking in order of importance to confirm the experts' agreement on their order. The outcome of this second ranking process (Table 6) showed that since the level of agreement on the relative importance of each question was higher than previously (Kendall's tau coefficient of concordance: 0.65, Friedman's test statistic p=0.0001), the questions had been appropriately refined to meet the panel's expectations. Meanwhile, we developed causal pathways for each of the questions (Tables 7-10) and submitted them to the TOO and the technical experts to be discussed at the second conference call, which was held to discuss each of the four key questions separately and extensively, to inform the technical experts about the adequacy of the literature on these questions, to refine the questions further if needed, and to discuss strategies for conducting the synthesis of the data.

Table 6. Outcome of ranking of the four refined key questions

| Question 1 | Question 2 | Question 3 | Question 4
Expert | Question 1 | Question 2 | Question 3 | Question 4
A
B | 4 | 3 | 2 | 1
C | 4 | 3 | 1 | 2
D | 4 | 3 | 1 | 2
E | 4 | 3 | 1 | 2
F
G
H
I | 4 | 1 | 3 | 2
J | 3 | 4 | 2 | 1
K | 4 | 2 | 3 | 1
L
M | 3 | 4 | 1 | 2
N | 4 | 3 | 2 | 0
O | 3 | 4 | 1 | 2
P
Q | 4 | 3 | 2 | 1
TOTAL | 41 | 33 | 19 | 16

Notes: The technical experts were asked to rank the questions on a scale of 4 (most important) to 1 (least important). Blanks indicate no response received.

### Question on Methods of Prevention (Table 5, Question 1)

All the participants agreed that LDH, low-molecular-weight heparin (LMWH), and SCDs are the most commonly used methods of prophylaxis and should be the focus of our literature search. Data on other methods, such as dextran, warfarin, or dihydroergotamine, should be also collected and analyzed if possible. The causal pathway for this question (Table 7) indicated that efficacy and safety would be the primary focus of evaluation. Cost-effectiveness of specific methods would also be examined.

Table 7. Causal pathway for question 1: Methods of prevention of venous thromboembolism

[image]

### Question on Identification of High-Risk Groups (Table 5, Question 2)

The technical experts agreed that there were no uniformly accepted criteria for identifying trauma patients at high risk for developing VT. Although some proposals for high-risk criteria have been published, they have not been extensively validated. The panel did not reach consensus on this question. It was suggested that we should investigate all the published criteria and analyze those most frequently used. The causal pathway developed for this question (Table 8) specified a variety of risk factors, which were grouped into the following categories: preexisting conditions, type of injuries, physiologic criteria, and iatrogenic factors. This grouping would be maintained during literature review and data synthesis only if possible.

Table 8. Causal pathway for question 2: Groups at high risk for venous thromboembolism

[image]

DVT, deep venous thrombosis; MI, myocardial infarction; CHF, congestive heart failure; PEEP, positive end-expiratory pressure.

### Question on Methods of Screening (Table 5, Question 3)

The panel agreed that the term "screening" pertains only to DVT. No routine screening is done for PE, which is diagnosed on the basis of clinical suspicion. The experts suggested that clinical examination should not be included as a method of screening because it does not reliably detect DVT in severely injured patients. Some experts recommended that impedance plethysmography should also be excluded because it is not widely used for trauma patients. Because everyone agreed that the two most important screening methods are Duplex scanning and venography, it was again proposed that a comparison of these two might be obsolete: Venography could be more sensitive in detecting DVT, but the Duplex scan is more convenient and safe for injured patients in the intensive care unit. However, the panel decided that the literature should be assessed because information on the timing, frequency, and cost-effectiveness of screening methods could be extracted. Other methods, such as impedance plethysmography or D-dimers, would be analyzed if adequate data were available. The major characteristics that would determine the superiority of a test (indicated by thick arrows in Table 9) were sensitivity/specificity, safety, applicability, and cost-effectiveness. Other characteristics (indicated by thin arrows in Table 9) were thought to be secondary, though important. Data on the timing of screening methods would also be extracted.

Table 9. Causal pathway for question 3: Best method of screening

[image]

ICU, intensive care unit.

### Question on the Role of Vena Cava Filters (Table 5, Question 4)

The panel was informed that our preliminary literature review identified several studies addressing this question, but none were RCTs. Many experts were concerned because several devices are available, which might make study results difficult to compare. Other experts believed that the evidence was not sufficient and might require too many extrapolations to analyze its cost-effectiveness. However, a suggestion was made to synthesize the existing data, if only to determine that the evidence is not sufficient for solid conclusions. All but three technical experts agreed to retain this topic as one of the key questions, but it was given the lowest priority. The causal pathway developed for this question (see Table 10) lists possible reasons for VCF insertion and issues relating to its safety and efficacy. The experts agreed that these issues should be researched in the literature.

Table 10. Causal pathway for question 4: Role of vena cava filters for prevention of venous thromboembolism

1 Reasons for VCF insertion; - Contraindications to heparin; - Permanent paralysis; - Long-term immobilization; - Very high risk for PE; - Breakthrough PE (despite heparin administration); - Recurrent PE; 2 Efficacy; - Decrease in PE rate; - Decrease in rate of death from PE; 3 Safety; - Incidence of DVT/postphlebitic syndrome; - Complications; - malplacement; - dislodgment and migration; - perforation of vital structures (heart, veins); - breakthrough PE

VCF, vena cava filter; PE, pulmonary embolism; DVT, deep venous thrombosis.

## Literature Search

A librarian with special training in literature retrieval for evidence-based projects conducted the literature searches. Core project staff selected the terms used, with input from the entire project staff and the technical experts.

### Strategy and Execution

Three major databases (MEDLINE, EMBASE, and the Cochrane Controlled Trials Register) were searched according to the following strategy:

- Prior to the conference calls, a preliminary search was performed on MEDLINE (English-language articles only) to estimate the amount and type of evidence available.
- Following the suggestions by the technical experts, the formal computer-aided literature search was performed on all three databases using OVID: MEDLINE was searched from 1966 through January 1999, EMBASE from 1980 through January 1999, and Cochrane from May 1991 through January 1999. All languages were included. Terms used included the following medical subject headings: -Thrombophlebitis -Thrombosis -Thromboembolism -Pulmonary embolism -Wounds and injuries the subheadings: -pc (prevention and control) -in (injuries) and the text words: -prevent$ -thromboprophyla$ -prophylac$ -trauma$ -posttrauma$ -post-trauma$.

Tables 11 through 13 list the complete set of search terms. Supplemental searches were performed to identify studies that addressed specific topics referring to the key questions and topics that might be missed by the broad search. Supplemental searches were performed on the adverse effects of the drugs and devices used to prevent VT (Table 14), on screening for VT (Table 15), and on the cost of prophylaxis for VT (Table 16). As the final step of the formal literature search, we included a broad search on the prevention of VT in all types of patients (not specifically in trauma patients) to ensure that no relevant studies were missed (Table 17).

Table 11. Prevention of venous thromboembolism after injury: Literature search in MEDLINE (1966--January 31, 1999) using OVID

1 *thrombosis/ or *thrombophlebitis/ or *pulmonary embolism/ or *thromboembolism/; 2 (trauma$ or posttrauma$ or post-trauma$).mp.; 3 in.fs.; 4 exp "wounds and injuries"/; 5 2 or 3 or 4; 6 1 and 5; 7 thrombosis/pc or thrombophlebitis/pc or pulmonary embolism/pc or thromboembolism/pc; 8 6 and 7; 9 (prevent$ or prophyla$ or thromboprophyla$).mp.; 10 6 and 9; 11 8 or 10; 12 limit 11 to animal; 13 limit 11 to human; 14 12 and 13; 15 11 not 12; 16 15 or 14; 17 16 not letter.pt.; 18 17 not editorial.pt.; 19 18 not case report/; 20 case report/ and clinical trial.pt.; 21 18 and 20; 22 19 or 21

Table 12. Prevention of venous thromboembolism after injury: Literature search in EMBASE (1980--January 31, 1999) using OVID

1 *Deep vein thrombosis/; 2 *Leg thrombosis/; 3 *Thrombosis/ or *Thrombosis prevention/ or *Vein thrombosis/; 4 *Thromboembolism/; 5 *Lung embolism/; 6 (venous and thrombosis).ti.; 7 1 or 2 or 3 or 4 or 5 or 6; 8 *Thrombophlebitis/; 9 7 or 8; 10 (trauma$3 or postrauma$3).mp.; 11 exp Injury/; 12 (injur$3 or fracture$1).mp.; 13 10 or 11 or 12; 14 9 and 13; 15 limit 14 to human; 16 Case control study/ or Case study/ or Clinical article/ or Clinical study/ or Clinical trial/ or Major clinical study/ or Prospective study/ or Retrospective study/; 17 Cohort analysis/; 18 exp Clinical trial/; 19 Meta analysis/; 20 exp Practice guideline/; 21 Randomized controlled trial/; 22 16 or 17 or 18 or 19 or 20 or 21; 23 15 and 22

Table 13. Prevention of venous thromboembolism after injury: Literature search in Cochrane controlled trials register (1980--January 31, 1999) using OVID

(VEIN next THROMBOSIS or DEEP next VEIN next THROMBOSIS or DVT or THROMBOPHLEBITIS or PULMONARY next EMBOLISM or LUNG next EMBOLISM or THROMBOEMBOLSM or VENOUS next THROMBOSIS) not MEDLINE not EMBASE

Table 14. Adverse effects of prophylaxis for venous thromboembolism: Supplemental literature search in MEDLINE (1966--January 31, 1999) using OVID

1 exp heparin/ae,to,ct; 2 exp dextrans/ae,to,ct; 3 ancrod/ae,to,ct; 4 hirudin/ae,to,ct; 5 1 or 2 or 3 or 4; 6 Vena cava filters/ae,ct [Adverse Effects, Contraindications]; 7 (((foot adj3 pump$1) or calf) adj3 pump$1).mp. [mp=title, abstract, registry number word, mesh subject heading]; 8 7 and (ae or co).fs.; 9 stockings.mp.; 10 9 and (ae or co).fs.; 11 (((((sequential adj4 compression) or intermittent) adj4 compression) or pneumatic) adj4 compression).mp. [mp=title, abstract, registry number word, mesh subject heading]; 12 11 and (ae or co).fs.; 13 Ultrasonography, doppler/ae,ct [Adverse Effects, Contraindications]; 14 exp Ultrasonography, doppler, Duplex/ae,ct [Adverse Effects, Contraindications]; 15 Ultrasonography, doppler, pulsed/ae [Adverse Effects]; 16 Phlebography/ae,ct [Adverse Effects, Contraindications]; 17 Thrombelastography/ae [Adverse Effects]; 18 exp Plethysmography/ae [Adverse Effects]; 19 dimer$1.mp. and (to or ae or co or ct).fs. [mp=title, abstract, registry number word, mesh subject heading]; 20 thrombosis/ or thromboembolism/ or thrombophlebitis/ or pulmonary embolism/; 21 19 and 20; 22 5 or 6 or 7 or 8 or 10 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 21; 23 22 and su.fs.; 24 22 and surgical.mp.; 25 22 and surgery.mp.; 26 22 and trauma$3.mp.; 27 22 and posttrauma$3.mp.; 28 exp "Wounds and injuries"/; 29 22 and 28; 30 22 and in.fs.; 31 23 or 24 or 25 or 26 or 27 or 29 or 30; 32 31 not letter.pt.; 33 32 not editorial.pt.; 34 33 not review.pt.; 35 case report/ and clinical trial.pt.; 36 34 and 35; 37 34 not case report/; 38 36 or 37; 39 limit 38 to animal; 40 limit 39 to human; 41 38 not 39; 42 40 or 41; 43 meta-analysis/; 44 meta-analysis.pt.; 45 medline.ti,ab.; 46 ((metaanaly$ or meta) adj analy$5).ti,ab.; 47 overview$.ti,ab.; 48 systematic review$.ti,ab.; 49 43 or 44 or 45 or 46 or 47 or 48; 50 33 and 49; 51 50 or 42

Table 15. Screening for venous thromboembolism: Supplemental literature search in MEDLINE (1966--January 31, 1999) using OVID

1 thrombosis/ra,ri,us; 2 thrombophlebitis/ra,ri,us; 3 thromboembolism/ra,ri,us; 4 pulmonary embolism/ra,ri,us; 5 1 or 2 or 3 or 4; 6 thrombosis/ or thromboembolism/ or thrombophlebitis/ or pulmonary embolism/; 7 exp ultrasonography, doppler/; 8 phlebography/; 9 thrombelastography/; 10 exp plethysmography/; 11 (doppler or Duplex or venogram$ or venography or ipg).mp.; 12 (ultrasound or ultrasonography).mp.; 13 dimer$1.mp.; 14 screen$3.mp.; 15 or/7-14; 16 6 and 15; 17 5 or 16; 18 (trauma$3 or posttrauma$3 or post-trauma$3).mp.; 19 in.fs.; 20 exp "wounds and injuries"/; 21 18 or 19 or 20; 22 17 and 21; 23 limit 22 to animal; 24 limit 23 to human; 25 22 not 23; 26 24 or 25; 27 26 not letter.pt.; 28 27 not editorial.pt.; 29 28 not review.pt.; 30 case report/ and clinical trial.pt.; 31 29 not case report/; 32 29 and 30; 33 31 or 32; 34 meta-analysis/; 35 meta-analysis.pt.; 36 medline.ti,ab.; 37 ((metaanaly$ or meta) adj analy$5).ti,ab.; 38 overview$.ti,ab.; 39 systematic review$.ti,ab.; 40 34 or 35 or 36 or 37 or 38 or 39; 41 40 and 26; 42 33 or 41

Table 16. Cost of prevention for venous thromboembolism: Supplemental literature search in MEDLINE (1966--January 31, 1999) using OVID

1 thrombosis/ec or thrombophlebitis/ec or thromboembolism/ec or pulmonary embolism/ec; 2 *thrombosis/ or *thromboembolism/ or *pulmonary embolism/ or *thrombophlebitis/; 3 exp cost allocation/ or exp cost control/ or exp cost of illness/ or exp cost-benefit analysis/ or exp health care costs/ or "Costs and cost analysis"/; 4 2 and 3; 5 1 or 3; 6 5 not letter.pt.

Table 17. Prevention of venous thromboembolism in all types of patients: Inclusive literature search in MEDLINE (1966--January 31, 1999) using OVID

1 *thrombosis/ or *thrombophlebitis/ or *thromboembolism/ or *pulmonary embolism/; 2 thrombosis/pc or thrombophlebitis/pc or thromboembolism/pc or pulmonary embolism/pc; 3 (prevent$ or thromboprophyla$ or prophyla$).mp.; 4 1 and 3; 5 1 and 2; 6 4 or 5; 7 exp heparin/ or ancrod/ or hirudin/ or exp dextrans/; 8 stockings.mp.; 9 (vena cava filter$ or vena cava filter$).mp.; 10 ((sequential adj4 compression) or (intermittent adj4 compression) or (pneumatic adj4 compression)).mp.; 11 (vena cava filter$ or vena cava filter$).mp.; 12 (greenfield adj4 filter$).mp.; 13 ((foot adj3 pump$) or (calf adj3 pump$)).mp.; 14 ((suprarenal adj3 filter$) or (umbrella adj3 filter$) or mobin$).mp.; 15 (cava interruption$ or caval interruption$ or ivc interruption$).mp.; 16 thrombosis/ or thromboembolism/ or thrombophlebitis/ or pulmonary embolism/; 17 3 and 7 and 16; 18 or/8-15; 19 16 and 18; 20 6 or 19 or 17; 21 20 not letter.pt.; 22 21 not editorial.pt.; 23 22 not case report/; 24 case report/ and clinical trial.pt.; 25 22 and 24; 26 23 or 25; 27 meta-analysis/; 28 meta-analysis.pt.; 29 medline.ti,ab.; 30 ((metaanaly$ or meta) adj analy$5).ti,ab.; 31 overview$.ti,ab.; 32 systematic review$.ti,ab.; 33 27 or 28 or 29 or 30 or 31 or 32; 34 26 and 33; 35 26 not review.pt.; 36 34 or 35; 37 exp research design/; 38 exp clinical trials/; 39 exp epidemiologic research design/; 40 exp epidemiologic study characteristics/; 41 comparative study/ or placebos/; 42 multicenter study.pt.; 43 random$.ti,ab.; 44 (double blind$ or triple blind$).mp.; 45 (clinical adj trial$).mp.; 46 placebo$.ti,ab.; 47 practice guideline$.mp,pt.; 48 feasibility studies/ or clinical protocols/; 49 exp treatment outcome/; 50 (volunteers or control$3).mp.; 51 clinical trial$.pt.; 52 (controlled clinical trial or randomized controlled trial).pt.; 53 or/37-52; 54 35 and 53; 55 34 or 54; 56 limit 55 to human; 57 limit 55 to animal; 58 55 not 57; 59 56 or 58

In addition to the computer-aided literature searches, we checked the bibliographies of relevant studies (particularly review articles) and of pertinent chapters of the textbook, Venous Thromboembolism: An Evidence-Based Atlas (Hull, Raskob, Pineo, eds., 1996). None of the relevant references found in these bibliographies had been missed by our computer searches.

After we had evaluated all the studies and identified all the important articles, we performed a final search only on RCTs on the prevention of VT in trauma patients (Table 18). No new relevant articles were found in this search.

Table 18. Prevention of venous thromboembolism after injury: Final repeat search on only randomized controlled trials in MEDLINE (1966--January 31, 1999) using OVID

1 thrombosis/pc or thromboembolism/pc or thrombophlebitis/pc or pulmonary embolism/pc; 2 thrombosis/ or thromboembolism/ or pulmonary embolism/ or thrombophlebitis/; 3 (thrombosis or thromboembolism or pulmonary embolism or thrombophlebitis or dvt or deep vein or venous thrombosis).mp.; 4 (prevent$ or prophyla$ or thromboprophyla$).mp.; 5 2 or 3; 6 4 and 5; 7 1 or 6; 8 7 and randomized controlled trial.pt.; 9 7 and clinical trial.pt. and random$.mp.; 10 (trauma$ or posttrauma$ or post-trauma$ or injury or injuries or nonsurgical or non-surgical or fracture$).mp.; 11 in.fs.; 12 exp "wounds and injuries"/; 13 10 or 11 or 12; 14 8 or 9; 15 13 and 14

## Design of the Database

To assemble and keep track of information from the literature reviews, one of the members of the core project staff designed a database in Microsoft Access^®^ with the assistance of professionals from Microsoft^®^. All literature searches were imported using electronic mail from the librarian's desk directly into the database. The acceptance or rejection of titles, abstracts, or papers was also done directly on the computers by assigning categories from menus that included the predefined screening criteria. Electronic forms were developed to document the process of screening titles, abstracts, and full papers. Additional electronic forms were created to organize and tabulate the quality of studies, risk factors, treatment groups, and outcomes. The database design provided multiple flexible methods to create electronic queries to manage the data, generate evidence tables, and compile the desired information.

### Title Screening Stage

A total of 4,093 titles were identified. Two nonblinded medical reviewers (a trauma surgeon with expertise in critical care and a clinical pharmacologist) independently screened all titles against inclusion and exclusion criteria (Table 19). Whenever the two reviewers disagreed, the Task Order Manager reviewed the titles, and then all three individuals met for a joint decision. If the title did not clearly merit exclusion, the article was accepted to the abstract review phase.

Table 19. Inclusion and exclusion criteria: Screening for titles

Inclusion Criteria | Exclusion Criteria
1 Trauma patients; 2 Orthopedic and neurosurgical trauma patients; - Orthopedic injuries; - Not inpatient therapy; - Spinal or head injuries; 3 General surgery (could not always exclude because it was unclear that it was only "elective"); 4 Methods of prevention; - Complications of prevention; - Compression stockings; - Heparin; - Vena cava filters; - Methods of prevention; 5 Methods of screening; 6 Reviews and meta-analyses; - Meta-analysis; - Review; - Cost-efficiency analysis; 7 Other; - VT etiology and incidence; - Diagnosis of DVT or PE; - Guidelines; - Other; - Background; - Clinical outcomes | 1 Non-surgical patients; - Atrial fibrillation; - Cardiac: not valve, not myocardial infarction; - Medicine patients; - Myocardial infarction; - Pediatrics; - Stroke; - Thrombolytic therapy; - Non-drug, non-compression treatment; - Outpatients; - Cardiac valve replacement; 2 Elective surgery patients; - Cardiac valve replacement; - Vascular surgery; - Gynecologic surgery; - Not trauma-related; - Elective general surgery; 3 Animal and laboratory studies; - Animal; - In vitro clotting; - Drug mechanism; 4 Other; - Cancer; - Ethics focus; - Treatment; - Arterial thrombosis; - Irrelevant topic; - Elderly patients

VT, venous thromboembolism; DVT, deep venous thrombosis; PE, pulmonary embolism.

Table 20 shows the results of the two reviewers' independent title screen. After reconciliation of disagreements between the reviewers, 2,437 (59.5 percent) of these titles were accepted and passed to the abstract review phase. Table 21 shows the outcomes of the title screen process.

Table 20. Outcome of independent title screen of 4,093 titles from the two medical reviewers, and reconciliation of disagreements

Reviewer No. 1 | Reviewer No. 2 | Total
Accept | Accept | 2,017 (49.3%)
Reject | Reject | 1,523 (37.2%)
| Subtotal | 3,540 (86.5%)
Accept | Reject | 117 (2.8%)
Reject | Accept | 436 (10.7%)
| Subtotal | 553 (13.5%)
Following Reconciliation
Accept | Accept | 2,437 (59.5%)
Reject | Reject | 1,656 (40.5%)

Table 21. Reasons for inclusion and exclusion in title screening of 4,093 article titles

Inclusion/Exclusion Criteria | Accept/Reject | N
Background | Accept | 66
Clinical outcomes | Accept | 118
Complications of prevention | Accept | 79
Compression stockings | Accept | 55
Cost-effectiveness issues | Accept | 44
Diagnosis of DVT or PE | Accept | 239
Duplicates of other articles (found retrospectively) | Accept | 43
General surgery | Accept | 156
Guidelines | Accept | 13
Meta-analysis | Accept | 16
Methods of prevention | Accept | 361
Orthopedic injuries | Accept | 115
Orthopedic operations | Accept | 342
Other | Accept | 32
Reviews | Accept | 46
Screening methods | Accept | 135
Spine or head injuries | Accept | 100
Trauma patients | Accept | 94
Vascular/trauma patients | Accept | 153
Vena cava filters | Accept | 184
Venous thromboembolism etiology and/or incidence | Accept | 46
TOTAL INCLUDED | | 2,437
Animal studies | Reject | 9
Arterial thrombosis | Reject | 54
Atrial fibrillation | Reject | 37
Cancer | Reject | 93
Cardiac valve replacement | Reject | 86
Cardiac: not valve, not MI | Reject | 115
Drug mechanism | Reject | 10
Elderly patients | Reject | 13
Ethnic focus | Reject | 11
Gynecologic surgery | Reject | 124
In vitro clotting studies | Reject | 52
Irrelevant topic | Reject | 762
Medicine patients | Reject | 25
Myocardial infarction | Reject | 69
Nondrug/noncompression treatment | Reject | 7
Outpatients | Reject | 25
Pediatrics | Reject | 65
Stroke | Reject | 33
Thrombolytic therapy | Reject | 25
Treatment | Reject | 41
TOTAL EXCLUDED | | 1,656

DVT, deep venous thrombosis; PE, pulmonary embolism; MI, myocardial infarction.

While the MEDLINE/EMBASE screen was in process, the Task Order Manager reviewed in parallel the literature search from the Cochrane database. This search was restricted to extract titles that had not been retrieved by the MEDLINE or EMBASE searches; therefore, the yield was low. Only two titles were added from the "Database of Abstracts of Reviews of Effectiveness" component of the Cochrane database. Both referred to unpublished conference presentations.

### Abstract Screening Stage

The selected abstracts were screened against predetermined inclusion and exclusion criteria (Table 22). The inclusion criteria were related directly to the four key questions. Abstracts were rejected if their material related to any of the following:

- Treatment of VT (instead of prevention).
- Diagnosis of VT (instead of screening).
- Elective surgery patients (instead of trauma).
- Burns (after recommendation from the technical experts).
- Study did not include humans (animals, experimental).
- Study was not designed as a research project (panel discussions, editorials, letters, etc.).
- Study addressed an irrelevant topic.

Table 22. Inclusion and exclusion criteria: Screening for abstracts

Inclusion Criteria; - Trauma patients; - Methods of prevention; - High-risk group; - Screening methods; - Vena cava filters in trauma
Exclusion Criteria; - Diagnosis/treatment of venous thromboembolism; - Methods of diagnosis of venous thromboembolism; - Nontrauma: orthopedic or neurosurgical patients; - Irrelevant topic; - Elective operations; - Nonclinical studies; - Inappropriate study design (panel discussion, comments, letters, etc.); - Burns

The screening of abstracts was completed in a nonblinded fashion at meetings between the two medical reviewers and the Task Order Manager. Each abstract was discussed, and a consensus was reached on its acceptance or rejection. Titles without an abstract were accepted for retrieval of the full article. During the screening process, the inclusion and exclusion criteria were slightly revised to better reflect the populations studied.

Table 23 shows the final outcome of the abstract screening phase. A total of 271 abstracts passed to the article retrieval phase. Even if they did not strictly refer to trauma patients, abstracts on meta-analysis and cost-effectiveness analysis (44 studies) were accepted for retrieval in order to assess the methods and references used in similar studies. Two hundred twenty-six abstracts of original research studies were accepted for complete review.

Table 23. Results of abstract screening of 2,437 abstracts

Inclusion/Exclusion Criterion | Accept/Reject | N
Trauma | Accept | 79
Head/spinal-cord injury | Accept | 40
Trauma/orthopedic injuries | Accept | 81
Possibly trauma | Accept | 12
Screening methods | Accept | 4
Vena cava filters | Accept | 11
Economic ^1^ | Accept | 25
Meta-analysis ^1^ | Accept | 19
Total Articles Retrieved | | 271
Diagnosis/treatment of venous thromboembolism | Reject | 127
Elective surgery | Reject | 254
Healthy volunteers | Reject | 8
Nontrauma orthopedic or neurosurgical patients | Reject | 450
Irrelevant topic/inappropriate study design | Reject | 1,327
Total Articles Rejected | | 2,166
Total | | 2,437

1 Articles retrieved for useful background material only; not intended for analysis.

## Data Collection Forms

The core project staff designed data-collection forms and tested data entry from 20 studies into the forms. After revisions, the forms were approved by the TOO and the entire group (Appendix A). The final form had three sections: a General Information front page, a Quality Screen, and an Evaluation Form.

### General Information Page

The General Information page included:

- A list of the rejection criteria because some titles had been retrieved without an abstract review and other articles were found to be inappropriate although the abstract had seemed appropriate.
- The four key questions in order to identify the question(s) addressed by the study.
- A list of different trauma populations to standardize coding of the populations used in all studies.

Each study was again evaluated against the rejection criteria. If the study was accepted, the key question(s) it addressed were identified and ranked in order of importance in the study design. The trauma population studied was also identified (e.g., neurosurgical trauma, orthopedic trauma, minor trauma).

### Quality Screening Page

The Quality Screen consisted of a list of study designs (e.g., RCT, natural history/ observational/longitudinal single cohort, prospective comparative cohorts). Following discussion with our statistician, each study design was assigned a list of criteria by which its quality could be ranked. For controlled trials, the quality filters and the scoring system were based on the work of Jadad and Shulz and their colleagues (Jadad, Moore, Carroll, et al., 1996; Schulz, Chalmers, Hayes, et al., 1995). The criteria used in this score assessed randomization, blinding, withdrawals and dropouts. For other designs, we used the quality filters described by Sackett (Sackett, 1981). These quality filters assessed inclusion and exclusion criteria, inception point, followup, withdrawals and dropouts, objectivity of outcome criteria, blind assessment of outcome, adjustment for extraneous factors, and pathways for inclusion of patients. If an article met the criterion, it received 1 point, and if it did not meet the criterion, it received 0 points (except for two criteria in RCTs where -1 points could be given). For RCTs, Jadad's summary score can range from 0 to 5 points and has been empirically shown to be associated with bias using a threshold of greater than or equal to 3 points vs. 0 to 2 points (Moher, Jadad, and Klassen, 1998). For cohort studies, the summary score ranges from 0 to 5 (single-cohort studies) or 3 to 6 (comparative-cohort studies). Thus, all articles of the same design can be compared using a point score.

### Evaluation Form

The Evaluation Form consisted of several subforms: Face Sheet, Demographics, Group Description, Methods of Screening, Risk Factors, and Outcomes. The Face Sheet included identifying information about the study and a narrative description. The Demographics form listed demographic data reported by the study for "All" patients and, if available, by the groups compared in the study. If the study compared two or more groups, we entered the defining attributes of the assigned groups on the Group Description form. The Methods of Screening form was only used for studies that compared two methods of screening. The Risk Factors form was only used for studies that published data on risk factors that were continuous variables (e.g., age). When risk factors were derived from dichotomous variables, they were reported on the Outcome Form. The Outcome form listed outcomes (DVT, PE, adverse events) by group or by risk factor, depending on what was reported.

### Article Screen

All articles but one (a Turkish-language article not found after two requests through the library to the national retrieval network) were retrieved (225 articles total). Two medical reviewers and the Task Order Manager reviewed the studies in a nonblinded fashion and completed the data-collection forms. Two independent reviewers screened every study: each medical reviewer screened half of the studies, and the Task Order Manager screened all the studies. Disagreements and inconsistencies were resolved in a meeting with all three reviewers. Translators with a medical background were used for a number of foreign-language articles.

Only studies that passed the Front Page "revisiting the rejection criteria" screen were evaluated. Table 24 presents the number of studies excluded and the reason for their rejection during the article-screening phase. A total of 73 studies were ultimately accepted and reviewed and had the Quality Screen and Evaluation Form sections completed. Table 25 lists these studies and their country, language of publication, and target population.

Table 24. Reasons for exclusion of 152 of 225 retrieved full studies after revisiting the rejection criteria

Rejection Criterion | No. of Articles
Irrelevant topic (laboratory, animals, therapy, etc.) | 15
Irrelevant population (elderly, medical, etc.) | 79
Method of prophylaxis after elective surgery | 11
Inappropriate study category (review, editorial, etc.) | 17
Other
Same patients as another accepted study | 7
Old study or old drug no longer used | 5
Patients with established DVT or PE | 3
Cost-effectiveness in different populations | 2
Inadequate or unreliable data | 9
Causes of thrombosis | 1
Does not address any of the four questions | 3
Total | 152

DVT, deep venous thrombosis; PE, pulmonary embolism.

Table 25. The 73 accepted studies by country, language of publication, and target population

Country | No. of Accepted Studies
Australia | 1
Belgium | 1
Canada | 6
England | 1
Finland | 1
France | 1
Germany | 4
Poland | 1
Spain | 1
Switzerland | 1
USA | 55
Language of Publication | No. of Accepted Studies
English | 67
French | 2
German | 3
Polish | 1
Target Population | No. of Accepted Studies
General trauma | 33
Orthopedic trauma | 10
Neurosurgical trauma | 26
Minor trauma | 4

### Reconfiguring the Articles

One of the 73 studies (Knudson, Lewis, Clinton, et al., 1994) included three separate RCTs different methods of prophylaxis. With the authors' permission, we treated this study as three different papers for data analysis. Three other studies, produced at another institution, covered the same period of time and the same population: One study included all trauma patients, another only trauma patients with orthopedic injuries, and a third only trauma patients with neurosurgical injuries (Rogers, Shackford, Ricci, et al., 1997; Rogers, Strindberg, Shackford, et al., 1998; Wilson, Rogers, Wald, et al., 1994). We included all three studies but used them selectively. When analyzing the entire trauma population, we included only the largest study (Rogers, Strindberg, Shackford, et al, 1998). The other two studies were included only when we performed supplemental analyses of the orthopedic or neurosurgical trauma patients.

### Quality of Studies

Among 73studies, there were the following:

- Nineteen randomized controlled trials.
- Seventeen comparative-cohort studies (8 comparing two prospective study cohorts, 7 comparing a prospective cohort with a retrospective cohort, and 2 comparing two retrospective cohorts).
- Thirty-seven single-cohort, observational prospective, or retrospective studies.

Table 26 shows the quality scores according to study design. Approximately two-thirds of the RCTs, one-third of the single-cohort studies, and three-fourths of the comparative-cohort studies received quality scores that were lower than the median of the highest possible score for the category (e.g., 3 on a scale of 0 to 5). Figure 1 shows the variation of quality scores among studies.

Table 26. Quality scores of the 73 accepted studies by study design

Design | Range of Quality Scores (median quality score) | Number of Studies | Mean Quality Score ± SD | Number of Studies with Quality Score > Median Quality Score
Randomized controlled trial | 0 to 5 (3) | 19 | 2.1 ± 1.6 | 6 (32%)
Single-cohort study | 0 to 5 (3) | 37 | 1.9 ± 1.3 | 11 (30%)
Comparative-cohort study | 0 to 8 (4) | 17 | 4.0 ± 1.9 | 13 (76%)

SD, standard deviation.

Figure 1. Quality scores of the 73 accepted studies according to study design

## Synthesis of Existing Data

From the accepted studies, we produced the following:

- Evidence tables for each study.
- Calculations of the incidence of DVT and PE.
- Meta-analysis and supplemental analyses for each of the four questions.

### Method of Meta-Analysis

We used meta-analysis for all comparisons between two methods of prophylaxis (Question 1). The outcome was always DVT or PE.

#### Step 1

For each study, we first entered the following information into an Statistical Analysis System (SAS) program and converted it into an SAS data set:

- Study identification number.
- Author and year of publication.
- The number of DVT/PE occurrences in the treatment group.
- The number of patients in the treatment group.
- The number of DVT/PE occurrences in the control group.
- The number of patients in the control group.

#### Step 2

The following statistics were generated by the data entered above:

- Study-level statistics (incidence, relative risk, risk of difference, number needed to treat [NNT], odds ratio, and their 95 percent confidence intervals).
- Crude estimates and their 95 percent confidence intervals for all studies combined.
- Fixed-effects estimates and their 95 percent confidence intervals for all studies combined.
- Random-effects estimates and their 95 percent confidence intervals based on the DerSimonian and Laird (D-L) method for all studies combined (DerSimonian and Laird, 1986), and chi-squared test of homogeneity.
- Weight for each study for both the fixed-effects model and random-effects model in calculation of odds ratio, risk difference, and relative risk (Laird and Mosteller, 1990).

We used the DerSimonian and Laird random-effects model to pool effect sizes across studies (DerSimonian and Laird, 1986). This method produces a summary measure that is a weighted mean. It weights each study's measure by the inverse of the sum of the within-study variance and the between-study variance. This approach allows both sampling variation and between-study heterogeneity to affect the pooled estimate.

In addition to the pooled estimate, we calculated the Q-statistic and p value for the chi-squared test of heterogeneity, which tests the null hypothesis that the individual study results are homogenous (Laird and Mosteller, 1990). Since the test is known to lack power to detect heterogeneity, we protected against spurious conclusions resulting from combining clinically heterogeneous patients or treatments in two ways, regardless of the outcome of the chi-squared test of heterogeneity. First, we used the random-effects estimates, which incorporate some between-study variance even if the chi-squared test does not reject it. Second, we planned subgroup analyses to assess outcome estimates in more homogeneous populations.

#### Step 3

We used a SAS macro software program developed by the RAND statistical staff to perform all meta-analyses, and we used the beta-test version of the software package "MetaGraphs" (1998; Belmont Research, Inc., 84 Sherman Street, Cambridge, MA 02140) for graphing funnel and shrinkage plots. (The funnel plots help screen for possible publication bias, whereas the shrinkage plots display the effect size of each study.) To create the graphs, we had to enter the data into ASCII files using the UltraEdit-32 (v. 6.00, IDM Computers Solutions, Inc.) software. We used MetaGraph to convert the ASCII treatment file into a binary file. We produced two diagnostic graphs before creating the shrinkage graph. We used a L'Abbe plot, a bivariate plot of one treatment risk against the other treatment risk in each study, to determine the appropriate type of effect size.

The same meta-analytical procedures were used to examine various risk factors. We grouped studies that included the same risk factor together and calculated the outcome (DVT/PE) incidence in patients with the risk factor and in patients without the risk factor.

## Supplemental Analyses

We calculated the incidence of secondary outcomes such as fatal PE or complications of methods of prophylaxis. Because the data were very limited, different groups could not be compared.

### Cost-Effectiveness Methodology

The cost-effectiveness (C-E) analysis evaluated different approaches for preventing VT in major trauma patients. We did not include patients with minor trauma in this analysis because the available literature was limited. We used the TreeAge software program (TreeAge Software, Inc., Williamstown, MA) to develop an initial decision-tree model based on different outcome probabilities with regard to VT. We derived the incidences of most of the various outcomes from our meta-analysis. In areas not evaluated in the meta-analysis, we derived outcome rates from review of the literature. Outcomes with very low incidence (<1 percent) were eliminated to simplify the final decision-tree model (Figures 2 and 3).

Figures 2 and 3. Decision tree for diagnosis and treatment of venous thromboembolism

We made the following assumptions when we designed the decision-tree model:

- All patients' bilateral lower extremities were screened by Duplex ultrasonography once per week for as long as they were nonambulatory.
- The mean nonambulatory period was 2 weeks (Knudson, Collins, Goodman, et al., 1992).
- DVT found by Duplex was not confirmed by venography.
- DVT treatment consisted of intravenous heparin administered to achieve therapeutic levels (partial thromboplastin time [PTT] and international normalized ratio [INR] of at least twice normal).
- No routine screening for PE was performed, and the diagnosis was based on clinical symptoms.
- Diagnosis of PE consisted of ventilation-perfusion (V/Q) scan initially (Gottschalk, Bisesi, and Stein, 1996). If the V/Q scan indicated high probability for PE, the patient was treated. If the V/Q scan indicated intermediate probability, a pulmonary angiogram was performed and the patient was treated only if the angiogram was positive. If the V/Q scan indicated low probability or was normal, the patient was not treated.
- Each type of V/Q scan (high, intermediate, or low probability) was found in one-third of patients evaluated for PE.
- Intravenous heparin was used to treat PE. A vena cava filter was used only if there was contraindication to full heparinization (estimated to occur in 20 percent of patients). Our model did not include the prophylactic use of vena cava filters in high-risk patients.
- "Breakthrough" PEs that occurred despite adequate treatment with intravenous heparin were given a probability of less than 1 percent and were eliminated from the refined model.

The following indices were based on our meta-analysis or individual literature data:

- The incidence of adverse reactions after administration of VT prophylaxis was the same for LDH and LMWH (3 percent; range 2 percent to 4 percent), as shown by our analysis (see Chapter 4. Supplemental Analysis:Analysis of Complications of Methods of VT Prevention). SCDs were associated with no adverse reactions.
- The incidence of DVT in patients with or without prophylaxis was 12 percent (range 10 percent to 13 percent), as shown by our analysis (see Chapter 3. Results: Incidence of DVT and PE in Trauma Patients).
- The sensitivity of Duplex ultrasonography in detecting lower-extremity DVT was 80 percent (Lensing, Davidson, Prins, et al., 1996). The incidence of false negatives was 20 percent.
- The incidence of adverse reactions to full heparinization for established DVT was 11 percent (Hull, Raskob, Rosenbloom, et al., 1990).
- In the absence of reliable data, the incidence of death related directly to adverse reactions following full heparinization was arbitrarily placed at 5 percent of the patients who developed adverse reactions.
- The incidence of patients who developed PE after a falsely negative Duplex scan was 3 percent, as shown by our analysis (see Chapter 3. Results: Incidence of DVT and PE in Trauma Patients). Although our evidence report found the overall incidence of PE to be 1.5 percent, we used the highest end of the 95 percent confidence interval (1 percent to 3 percent) because we believe that the existing literature data show artificially low rates of PE because of insufficient index of suspicion and diagnostic evaluation. Other studies in surgical nontrauma patients show incidences of PE that range between 20 percent and 50 percent in patients who have unrecognized, and therefore untreated, DVT (Brandjes, Heijboer, Buller, et al., 1992; Hull, Raskob, Hirsh et al., 1986).
- The incidence of fatal PE in those with PE was 30 percent, as shown by our analysis (see Chapter 4. Supplemental Analysis: Incidence of Fatal PE).
- The incidence of false-negative V/Q scan (normal or low probability) was 14 percent (PIOPED Investigators, 1990).
- The incidence of death in patients with missed diagnosis of PE (false-negative V/Q scan) was 25 percent (Barritt and Jordan, 1960).
- The incidence of adverse reactions in patients who received heparin for treatment of PE was the same as the incidence in those receiving heparin for treatment of DVT (11 percent). The incidence of adverse reactions in those who had contraindication to heparin (20 percent of patients diagnosed with PE) and received a vena cava filter as treatment of PE was 0.

The cost estimates used average wholesale prices for the cost of drugs. We derived the cost estimates for medical services associated with each outcome branch from the resource-based relative-value scale (RBRVS) (St. Anthony's Complete RBRVS, 1997) of the Health Care Financing Administration. When multiple RBRVS prices were listed, we used the lowest price. The analysis was restricted to prices in the United States.

Initially, we compared the cost-effectiveness of VT prophylaxis with no prophylaxis. VT prophylaxis could be provided by one of the three most commonly used methods: LDH, LMWH, or SCDs. Because the meta-analysis did not identify any difference in the incidence of VT between prophylaxis and no prophylaxis (see Chapter 3. Results), the two arms of the decision tree differed only with regard to the possibility of adverse reactions related to the method of prophylaxis.

Following the C-E analysis, we estimated the reduction in the incidence of VT that must be achieved by each of the three prophylactic methods relative to no prophylaxis in order to become cost-effective. The results of this sensitivity analysis will help future investigators to design clinical trials of different methods of VT prophylaxis with adequate power to detect the magnitude of differences in outcomes required for cost-effectiveness.