# Introduction

## Purpose

The purpose of this evidence report is to review the scientific literature to establish the incidence of venous thromboembolism (VT) after injury, evaluate the role of different methods of prophylaxis, and identify trauma patients who are at high risk for developing VT. This information will be made available to health care providers and organizations to assist them in treating these patients. Professional trauma societies may develop guidelines based on the existing evidence and use the guidelines to improve the care of patients with VT.

## Scope of Work

Initially, we found general information on all aspects of VT after injury, including the following:

- Incidence of VT in different trauma populations.
- Prevention and treatment of VT.
- Groups at risk.
- Methods of prevention and screening.
- Short- and long-term effects of VT.
- Adverse reactions to methods of prevention.
- Diagnostic tests.
- Cost-effectiveness of different methods of management.

Discussions with technical experts identified four key questions:

1 What is the best method of VT prophylaxis?
2 What groups of patients are at high risk of developing VT?
3 What is the best method of screening for VT?
4 What is the role of vena cava filters (VCFs) in preventing pulmonary embolism (PE)?

## Background and Description of the Problem

### Overview

VT is a major national health problem that takes a significant toll on lives and creates major disabilities. Although it is essentially one disease, VT presents in two forms: deep venous thrombosis (DVT) and PE. Each year, 50,000 people in the United States die from PE and between 300,000 and 600,000 hospitalizations are associated with DVT or PE (Consensus Conference, 1986). Although the incidence of PE has decreased over the last 20 years (Silverstein, Heit, Mohr, et al., 1998), the incidence of DVT remains unchanged or is increasing in specific populations. Death resulting from PE is not uncommon in surgical patients. PE has been discovered in 31.7 percent of surgical patients brought to autopsy, and it was considered to be the absolute or contributing cause of death in 55.5 percent of these cases (Lindblad, Eriksson, and Bergqvist, 1991).

### Sequelae of VT

DVT is a highly morbid condition that prolongs hospitalization, increases costs, and is associated with long-term sequelae, such as venous insufficiency and the postphlebitic syndrome, which occur in 30 to 50 percent of patients (Halstuk, Mahler, and Baker, 1984; Strandness, Langlois, Cramer, et al., 1983). A clot may become dislodged and impair circulation in the pulmonary arteries by embolization, creating PE, a potentially lethal complication. Proximal lower extremity DVTs are probably the source of the majority of PEs (Bergqvist and Lindblad, 1985), although the venous systems of the pelvis, neck, and upper extremities may also produce PEs.

The reported incidence of PE varies widely, from 0.3 to 30 percent (Burns, Cohn, Frumento, et al., 1993; Morris and Mitchell, 1976), because essentially no patients are routinely screened for PE. Diagnostic tests are almost always performed on the basis of clinical suspicion. However, the signs and symptoms of PE are nonspecific, and the incidence of "silent" PE in patients with DVT is substantial (Kriemer-Nielsen, Husted, Krusell, et al., 1994). Clinical diagnosis of PE is especially difficult in critically ill patients because of multiple confounding factors from associated illnesses. The exact percentage of fatal PE is unknown for the same reasons. Coon (1976) has documented that only a minority of patients with autopsy-proven PE received a definitive diagnosis of PE while alive. It is quite possible that up to 50 percent of untreated PEs may lead or directly contribute to patient demise (Smith, 1990; Turpie, 1986).

### How Trauma Induces VT

The human body defends against bleeding by generating fibrinogen and fibrin, which produce a physiologic clot that seals bleeding sites. Clot formation and lysis occur simultaneously during this process, thereby preventing pathologic thrombi from occluding the veins. Trauma alters these mechanisms, placing the patient at higher risk for VT. Trauma activates multiple acute phase proteins, generating an inflammatory cascade that includes the coagulation system (Dries, 1996). Although trauma affects both the extrinsic and intrinsic coagulation pathways, it predominantly triggers the extrinsic pathway by releasing tissue thromboplastin from the sites of injury. This disturbs the fibrinolytic process and increases the likelihood that pathologic thrombi will form, particularly in areas where blood flow is reduced or blocked. Thus, patients who remain immobilized after trauma are at serious risk of developing thrombosis of major veins (Kudsk, Fabian, Baum, et al., 1989).

The incidence of VT in trauma patients depends on multiple factors, including the severity of trauma, the site of injury, the type of operative intervention, the method of diagnosis, and the method of prophylaxis. Using venography, Geerts, Code, Jay, et al. (1994) reported an incidence of 57.6 percent of DVT in patients with major trauma. Velmahos, Nigro, Tatevossian, et al. (1998) used Duplex ultrasonographic screening to detect DVT in critically injured patients and found an incidence of 13 percent. Spain, Richardson, Polk, et al. (1997) detected DVT by clinical examination only in 5 percent of trauma patients at high risk for VT. Patients with spinal-cord injuries, lower extremity fractures, or extensive abdominal operations, particularly in the pelvic region, have a risk of developing DVT that reportedly ranges from 15 to 60 percent (Clagett and Reisch, 1988; Salzman, Harris, and DeSanctis, 1966; Weingarden, 1992). Thus, it becomes clear that the reported rates vary widely and the existing literature is confusing.

### Methods Used for Prevention of VT

Preventive treatment of VT is important because the disease may first appear as lethal PE. Since diagnosis based on clinical suspicion is not sensitive enough to detect all VTs, several methods of screening have been introduced. If diagnosis of VT was based only on clinical presentation, many patients would be exposed to unreasonable risk because the chance for effective treatment may have been already lost: Most patients who die of PE do so within 30 minutes of the acute event, before anticoagulant therapy is effective (Clagett, Anderson, Geerts, et al., 1998).

The introduction of heparin for prevention of VT was a major breakthrough in VT management. It has been convincingly shown that heparin, administered subcutaneously at low doses, significantly decreases the incidence of VT in patients undergoing elective surgical procedures (Kakkar, Corrigan, and Fossard, 1975; Nicolaides, 1972). The evidence is less convincing in trauma patients. Heparin is associated with significant complications, the most important of which are bleeding and thrombocytopenia (Kleinschmidt and Seyfert, 1995; Pachter and Riles, 1977; van Ooijen, 1986).

Alternative methods of prophylaxis with fewer side effects have been introduced with good results. Sequential compression devices (SCDs) can be used alone or in combination with low-dose heparin (LDH) for prevention of VT. An SCD prevents clotting by accelerating the venous flow at the area of compression and, more importantly, increasing systemic fibrinolytic activity (Comerota, Chouhan, Harada, et al., 1997). Despite contradictory results (Butson, 1981; Nicolaides, Miles, Hoare, et al., 1983), the lack of complications associated with this method has encouraged its widespread use. Arteriovenous foot pumps (AFPs) are similar to SCDs but are only applied around the foot.

Low-molecular-weight heparin (LMWH) has been proposed as a safer and more effective method for VT prophylaxis. Numerous studies have compared the safety and efficacy of LMWH with LDH in different populations, including elective surgical, orthopedic, and neurosurgical patients. Results vary from absolute superiority, to moderate improvement, to no difference, to worse results (Bergqvist, Matzsch, Burmark, et al., 1988; Green, Lee, Lim, et al., 1990; Kakkar, Cohen, Edmondson, et al., 1993). Although many other drugs and methods have been studied for prevention of VT, e.g., electrostimulation, dihydroergotamine, heparinoids, and antiplatelet agents, the three most commonly used methods of VT prophylaxis for trauma patients remain LDH, LMWH, and SCD.

### The Rationale for Evaluating Posttraumatic VT as a Separate Clinical Entity

Guidelines for preventing VT in trauma patients must be developed specifically for them. Trauma patients frequently developan acute inflammatory response, in which multiple proteins are activated that distort normal blood rheology and the delicate balance between the coagulation and fibrinolytic mechanisms (Dries, 1996). These changes to blood chemistryusually occur in young persons without previous medical problems or vascular diseases. In contrast, studies of VT prophylaxis in nontrauma populations often focus on elderly patients undergoing elective surgery who have multiple preexisting risk factors for VT.

Diagnosis of VT is particularly challenging in patients with severe trauma. Clinical examination is very unreliable. Fractures or operations on the lower extremities decrease the sensitivity of Duplex ultrasound (Agnelli, Volpato, Radicchia, et al., 1991), which is the most common method of diagnosis in severely injured patients. Other, more sensitive diagnostic methods such as phlebography or pulmonary arteriography are not feasible because critically ill patients must be transported for an extended period of time away from the "safe" environment of the intensive care unit (ICU). Thus, the difficulty of diagnosis increases the importance of prevention.

The comparative safety and efficacy of the various methods of prophylaxis are well established in nontrauma patients, but existing recommendations for trauma patients are still inconclusive. Each prophylactic method poses particular problems in trauma patients:

- Physicians are reluctant to administer LDH or LMWH to patients who are still at high risk of bleeding after trauma.
- SCDs cannot be applied when patients have lower extremity injuries, and their efficacy when placed in alternative sites is still unknown.
- VCFs have been used successfully for the prevention of PE, but their long-term effects have not been studied. The exact indications for VCF insertion need to be further explored.

### Summary

The wide variation in injury severity and physiologic response in trauma patients does not allow VT prevention to be standardized easily. Published studies on trauma patients deal with a variety of populations and report results that are often contradictory. The indications and methods of preventing VT in trauma patients should be explored separately from other populations that are not affected by similar physiologic insults. Critical evaluation of the existing evidence is necessary to identify the valid methods of managing VT and uncover the areas in which knowledge is limited or anecdotal, with the hope that future focused research will provide more definitive answers.