# Appendix C. Acronyms and Abbreviations

AAST: American Association for the Surgery of Trauma

ADRp: adverse drug reaction of prophylaxis for VT

ADRpe: adverse drug reaction of treatment for PE

ADRt: adverse drug reaction of treatment for DVT

AFP: arteriovenous foot pump (mechanical prophylaxis)

APTT: activated partial thromboplastin time

AVF: arterio-venous footpump

C-E: cost-effectiveness

CHF: congestive heart failure

CI: confidence interval

D: death

DHE: dihydroergotamine

D-L: DerSimonian and Laird

DVT: deep venous thrombosis

Dx: diagnosis

EAST: Eastern Association for the Surgery of Trauma

EPC: evidence-based center

False N: false negative

FX: fracture

GCS: Glasgow Coma Score

HC: heparin-calcium

HI: head injury

HIST: historical control group

ICU: intensive care unit

INR: international normalized ratio

IP: impedance plethysmography

IPG: impedance plethysmography (same as above)

ISS: Injury Severity Score

iv: intravenous

LBF: long-bone fracture

LDH: low-dose heparin

LMWH: low-molecular-weight heparin

LOS: length of stay

MI: infarction

MP: mechanical prophylaxis

NNT: number needed to treat

OR: odds ratio

PE: pulmonary embolism

PEEP: positive end-expiratory pressure

PROSP: prospective control group

PSP: pentosan sulfuric polyester

PTT: partial thromboplastin time

RBRVS: resource-based relative-value scale

RCT: randomized controlled trial

RTS: Revised Trauma Score

S: survival

SAS: Statistical Analytical System

SC: subcutaneously (in reference to LDH)

SCD: sequential compression device (mechanical prophylaxis)

SCI: spinal-cord injury

SD: standard deviation

SF: spinal fracture

TED: thromboembolic disease

TED hose: thigh-high antiembolic compression stockings

thr/cyt: thrombocytopenia

TOO: Task Order Officer

True P: true positive

Tx: treatment

U/S: ultrasound

USC: University of Southern California

VCF: vena cava filter

V/Q: ventilation/perfusion

VT: venous thromboembolism (includes DVT and PE)

WTA: Western Trauma Association