# Appendix B. Contributors and Peer Reviewers

- Task Order Manager:
- George C. Velmahos, M.D., Ph.D.

- Center Director:
- Paul Shekelle, M.D.

- Statistician/Meta-analyst:
- Linda S. Chan, Ph.D.

- Medical Reviewers:
- Jack Kern, Pharm.D.
- James A. Murray, M.D.

- Task Order Coordinator/Medical Writer:
- Danila Oder, B.A.

- Database Designer:
- Jack Kern, Pharm.D.

- Pharmacoeconomic Consultants:
- Jeff McCombs, Ph.D.
- Joel Hay, Ph.D.

- Research Librarian:
- Janet Nelson, M.L.S.

- Technical Experts:
- Thomas V. Berne, M.D.
- Edward E. Cornwel, III, M.D.
- Demetrios Demetriades, M.D., Ph.D.
- Richard A. Dorazio, M.D.
- Timothy C. Fabian, M.D.
- Lazar Greenfield, M.D.
- M. Margaret Knudson, M.D.
- Kenneth L. Mattox, M.D.
- William McGehee, M.D.
- Michael D. Pasquale, M.D.
- J. David Richardson, M.D.
- Frederick B. Rogers, M.D.
- C. William Schwab, M.D.
- Steven Shackford, M.D.
- Kenneth S. Waxman, M.D.
- Albert Yellin, M.D.

- Peer Reviewers:
- All technical experts
- Elaine Allen, Ph.D.
- Howard Belzberg, M.D.
- H. Gill Cryer, M.D.
- Donald Gaspard, M.D.
- William J. Gillespie, M.D.
- Lazar J. Greenfield, M.D.
- David B. Hoyt, M.D.
- John T. Owings, M.D.
- Basil A. Pruitt, Jr., M.D.
- William Shoemaker, M.D.