# Appendix A. Study Design

Ref. Num.: _____
Reviewer: JK = 1 JM = 2 GV = 3 | | /1
Journal: ______________________________ Year __________
Country _______________ Language _______________ | | /2
Institution ______________________________
Authors: ________________________________________
Title: __________________________________________________
Revisiting rejection criteria: If rejecting, circle the most general reason that applies:
Irrelevant topic (laboratory, animals, therapy, etc.) | R1 | /3
Irrelevant population (elderly, medical, stroke, cancer, minor trauma, etc.) | R2
Methods of prophylaxis after elective surgery (general, orthopedic, Neurosurgical, urologic, gynecologic, etc.) | R3
Inappropriate study category (review, editorial, meta-analysis, case-report, etc.) | R4
Other (explain) | R5

If accepted, Which question(s) does this study address? (If more than one, check by order of importance)
| Rank
Objective of the study | 1^st^ | 2^nd^ | 3^rd^ | 4^th^
Question A: Methods of prevention | 1 | 2 | 3 | 4 | /4
Question B: Identification of high-risk trauma groups | 1 | 2 | 3 | 4 | /5
Question C: Methods of screening | 1 | 2 | 3 | 4 | /6
Question D: Vena caval filters, SCD | 1 | 2 | 3 | 4 | /7

What kind of patients are included in this study? (may circle more than one)
| Yes | No
All trauma | 1 | 0 | /8
Major trauma | 1 | 0 | /9
Defined as ISS> __________ | | | /10
Severe trauma | 1 | 0 | /11
Defined as ISS> __________ | | | /12
Ortho trauma | 1 | 0 | /13
Head trauma | 1 | 0 | /14
Spine trauma | 1 | 0 | /15
Mixed (trauma & nontrauma | 1 | 0 | /16
Other: ______________________ | 1 | 0 | /17
Primary outcome variable: ______________ | Choose from: DVT, PE | | /18
Secondary outcome variable(s): ___________ | Death from PE, Bleeding, Thrombocytopenia, Post-thrombotic syndrome | | /19

STUDY DESIGN | | Yes
1. | Randomized controlled trial? | 1 | | | /20
2. | Non-randomized controlled trial? | 1
3. | Prospective comparative cohorts? | 1
4. | Prospective cohorts with retrospective control cohort? | 1
5. | Retrospective comparative cohorts? | 1
6. | Case control? | 1
7. | Case series or cross sectional? | 1
8. | Natural history/observational/longitudinal single cohort? | 1
9. | Unsure | 1
QUALITY OF CONTROLLED TRIALS | | Yes | No | Uns
10. | Was the study described as randomized? | 1 | 0 | | /21
11. | Was the study described as double-blinded? | 1 | 0 | | /22
12. | Was there a description of withdrawals and drop outs? | 1 | 0 | | /23
13. | Was the randomization procedure appropriate? | 1 | -1 | 0 | /24
14. | Was blinding procedure appropriate? | 1 | -1 | 0 | /25
15. | Total score | ____ | | | /26
QUALITY OF COHORT(S) STUDY Prospective cohort
16. | Was the study cohort(s) clearly defined? (Inclusion and exclusion criteria clearly spelled out) | 1 | 0 | | /27
17. | Was the study cohort(s) assembled at an early and uniform point ("inception") in the course of the illness? | 1 | 0 | | /28
18. | Were the pathways by which patients entered the study clearly described? | 1 | 0 | | /29
19. | Was complete follow-up achieved? | 1 | 0 | | /30
20. | Was there a description of withdrawals and drop-outs? | 1 | 0 | | /31
21. | Were objective outcome criteria developed and used? | 1 | 0 | | /32
22. | Was the primary outcome assessment "blind"? | 1 | 0 | | /33
23. | Was adjustment for extraneous prognostic factors carried out? | 1 | 0 | | /34
| Retrospective cohort | 1 | 0
24. | Was the study cohort(s) clearly defined? (Inclusion and exclusion criteria clearly spelled out) | 1 | 0 | | /35
25. | Was the study cohort(s) assembled at an early and uniform point ("inception") in the course of the illness? | 1 | 0 | | /36
26. | Were the pathways by which patients entered the study clearly described? | 1 | 0 | | /37
27. | Was complete follow-up achieved? | 1 | 0 | | /38
28. | Was there a description of withdrawals and drop-outs? | 1 | 0 | | /39
29. | Were objective outcome criteria developed and used? | 1 | 0 | | /40
30. | Was the primary outcome assessment "blind"? | 1 | 0 | | /41
31. | Was adjustment for extraneous prognostic factors carried out? | 1 | 0 | | /42
32. | Total Score (add scores for prospective and retrospective cohorts, divide by 2) | ____ | | | /43
QUALITY OF CASE CONTROL STUDY
33. | Was the source of cases identified? | 1 | 0 | | /44
34. | Was the source of controls identified? | 1 | 0 | | /45
35. | Was there blinded assessment of: eligibility of cases and controls? outcome? exposure? | 1 | 0 | | /46 /47 /48
36. | Were the matching criteria of cases and controls clearly spelled out? | 1 | 0 | | /49
37. | Were the criteria defining the cases clearly spelled out? | 1 | 0 | | /50
38. | Was the exposure status clearly defined? | 1 | 0 | | /51
39. | Was the duration of exposure defined? | 1 | 0 | | /52
40. | Was the temporal relation of the exposure to the case event clearly defined? | 1 | 0 | | /53
41. | Was there an adjustment in the analysis for known confounders not included in matching? | 1 | 0 | | /54
42. | Total score | ____ | | | /55
QUALITY OF SINGLE COHORT OBSERVATIONAL STUDY
| | Yes | No
43. | Was the outcome(s) of the study clearly defined? | 1 | 0 | | /56
44. | Was the time point(s) at which the outcome(s) was (were) measured clearly defined? | 1 | 0 | | /57
45. | Was the cohort of subjects followed without any intervention? | 1 | 0 | | /58
46. | Was there blinded assessment of the outcomes of the study? | 1 | 0 | | /59
47. | Were point estimates and measures of variability provided For the main outcome measure? | 1 | 0 | | /60
48. | Total score | ____ | | | /61

## Methods of Screening

Appendix A. Study Design

Appendix A. Study Design

Ref Num: ____ Author: ____ Reviewed by: ____ Date: ____
Group | #inGrp | Site of Test | #Neg | #Pos | #False Neg | #False Pos | Sensitivity | Specificity
Gold Std | | All
| | Below Knee
| | Knee to Pelvis
| | Pelvis
| | Other
Test I | | All
| | Below Knee
| | Knee to Pelvis
| | Pelvis
| | Other
Test II | | All
| | Below Knee
| | Knee to Pelvis
| | Pelvis
| | Other

## Cohort and Study Basics

Appendix A. Study Design

Appendix A. Study Design

Ref Num: ______ Author: ______ Reviewed by: ______ Date: ______
Type of Institution: 1. Teaching Hospital; 2. Public Hospital; 3. VA; 4. Private hospital; 5. Clinic
Region/Country: ______ Patients followed in hospital primarily: Yes/No Patients followed in the hospital and clinics: Yes/No
Inclusion criteria: ____________________________________________________________
Exclusion criteria: ____________________________________________________________
Definitions: Drug[LDH, LMWH(enoxaparin), DHE, Dextran], dose, sig, duration/SICKLE CELL DISEASE, brand, duration/VCF, brand, duration
Group A: __________________________________________________________________
Group B: __________________________________________________________________
Group C: __________________________________________________________________
Group D: __________________________________________________________________
Group E: __________________________________________________________________
Screening Method: Such as; Clinical, IPG, Ultrasound, Venography, Radiosotope scan, D-dimer
Routine: (device, start time, frequency: if suspect DVT or PE, follow-up test):

## Risk Factors

Appendix A. Study Design

Appendix A. Study Design

Ref Num: ______ Author: ______Reviewed by: ______ Date:______ #Subjects in Groups ok? Yes/No
(Age, obesity, Extremity fractures, Lower extremity fractures, Below-the-knee fractures, femur fractures, Pelvic fractures, spinal fractures, Spinal cord injuries, Severe head injuries)
Risk Factor | #RF | SubGroup | #Sub Grp | Non-Risk Factor | #Non Risk Factor | Outcome | #RF Out | RF Stat | #Non RF Out | Non RF Stat | Explanation

## Demographics

Appendix A. Study Design

Appendix A. Study Design

Ref Num: ______Author: ______Reviewed by: ______Date: ______ #Subjects in Groups ok? Yes/No
(Variables measured prospectively per group: eg. Preexisting factors such as Age, gender, and possibly Traumatic factors such as fractures and head injuries). Describe Blunt trauma as: road traffic accident, fall from height, ground-level fall (<5ft), assault, other minimal-force trauma.
Group | #Studied | Demographic | #Demo | Demo Std | Explanation

## Outcomes/ADR/AE

Appendix A. Study Design

Appendix A. Study Design

Ref Num: ______ Author: ______ Rev. by: ______ Date: ______ #Subjects in Groups ok? Yes/No
For outcomes, choose: DVT, Proximal DVT, PE, fatal PE, thrombocytopenia, bleeding, post-thrombotic syndrome
Write risk factor or outcome here
Group | # in Group | Subgroup | # in Subgp | # w/ RF#1 | # w/ RF#2 | # w/ RF#3 | # w/ RF#4 | # w/ RF#5 | # w/ Outc#1 | # w/ Outc#2 | # w/ Outc#3 | # w/ Outc#4 | # w/ Outc#5 | AE (describe)