# Results

## Results of Literature Searches

Results of the literature search and selection process are summarized in the literature flow diagram (Figure 2). Database searches resulted in 6,175 potentially relevant citations. After dual review of abstracts and titles, 1,069 articles were selected for full-text review. After dual review of full text articles, 71 studies (in 81 publications) were included. Data extraction and quality assessment tables for included studies by Key Question are available in Appendixes G and H.

Figure 2 Literature flow diagram

Abbreviations: CAM = complementary alternative medicine; CBT = cognitive behavioral therapy; KQ = Key Question.

* Cochrane databases include the Cochrane Central Register of Controlled Trials, Database of Abstracts of Reviews of Effects, Health Technology Assessment, National Health Sciences Economic Evaluation Database, and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, hand searching, suggested by experts, etc.

‡ Studies that provided data and contributed to the body of evidence were considered “included.”

§ Studies may have more than one published article, this number indicates the number of unique studies included; there were a total of 45 publications included.

║ Studies may have provided data for more than one treatment area

Figure 2 is a flow diagram that summarizes the search and selection of articles. There were 6,175 citations identified by searching MEDLINE, PsycINFO, Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and other sources including reference lists, hand searching, and suggestions by experts. Of these 5,106 were excluded at the abstract level because they did not address a key question. The remaining 1,069 articles were pulled for review at the full-text level to further review for inclusion. There were 980 full-text articles excluded for the following reasons: did not address a key question or meet inclusion criteria but provided background information only, wrong population, wrong intervention, wrong outcomes, wrong study design, wrong publication type, foreign language, inadequate duration or a review not meeting our requirements. 71 studies in 81 publications were included in the final report. 36 studies answered key question 1. 35 studies answered key question 2, there were 9 studies of medications, 7 of complementary alternative medicine approaches, 14 studies of cognitive behavioral therapies, 4 of exercise, and 4 used a combination of treatments. Several studies had more than 1 published article, a total of 45 published articles were included for key question 2. The flow diagram is also described in the report.

## Description of Included Studies

Of the 71 studies included in this review, 36 observational studies addressed Key Question 1, pertaining to aspects of diagnosis. Most were of fair-quality, enrolled predominantly female patients, had small sample sizes, and were conducted in the United States and Western Europe. Thirty-five randomized trials were included for Key Question 2, addressing the benefits and harms of interventions to treat myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS) (9 for medications; 7 for complementary and alternative medicine [CAM]; 14 for counseling and behavioral therapies; and 6 for exercise, including 4 comparing interventions). Most were of fair- or poor-quality, enrolled predominantly female patients from ME/CFS specialty clinics based on the CDC (Fukuda, 1994) or Oxford (Sharpe, 1991) case definition, had small sample sizes, and were conducted in the United States and Western Europe.

## Key Question 1 What methods are available to clinicians to diagnose ME/CFS, and what conditions are required to be ruled out or excluded before assigning a diagnosis of ME/CFS?

### Key Points

- Eight different case definitions have been used to identify patients with ME/CFS; all include a set of clinical criteria and are applied by clinicians.
- The Oxford (Sharpe, 1991) case definition has the least overlap with other definitions.
- Most ME/CFS case definitions require that other conditions be excluded prior to assigning a diagnosis of ME/CFS; however, no studies compared strategies for ruling out alternative diagnoses.

### Detailed Synthesis

Case definitions have evolved since the first set of clinical criteria were published by the Centers for Disease Control and Prevention (CDC) in 1988 (Table 2 below and Appendix I).10 Despite being developed as consensus guidelines and with endorsement of national groups, none of these published case definitions is agreed upon as the single preferred method for distinguishing ME/CFS from other conditions that may also present with fatigue. The Oxford (Sharpe, 1991) case definition requires the presence of the smallest symptom set (new onset of fatigue with impairment of physical and mental function), suggesting less specificity for ME/CFS.46 Four definitions are labeled as myalgic encephalomyelitis (ME) or ME/CFS and all of these require the presence of post-exertional malaise (PEM). All case definitions address the diagnostic workup that is required prior to diagnosing chronic fatigue syndrome (CFS).2,3,47,48 In general, prior to diagnosing ME/CFS, other explanations for fatigue must to be ruled out. Recommendations for workup are included with the published case definitions, but no studies specifically evaluated diagnostic workup strategies or compared strategies for ruling out alternative diagnoses prior to assigning a diagnosis of ME/CFS.

Table 2 Case definitions and criteria

Criteria | | ME ± CFS | | | | CFS
Criteria | | London ME Dowsett, 1994^47^ | Canadian ME/CFS Carruthers, 2003^2^ | Revised Canadian ME/CFS Jason, 2010^48^ | International ME Carruthers, 2011^3^ | CDC Holmes, 1988^10^ | Oxford Sharpe, 1991^46^ | CDC Fukuda, 1994^4^ | CDC Reeves, 2005^*,49^
General Physical | Fatigue | X | ≥ 6 months | ≥ 6 months | | ≥6 months | ≥ 6 months or >50% of time | ≥6months | ≥ 6 months
General Physical | Sudden or New Onset | | X^†^ | | | X^‡^ | X | | X^§^
General Physical | Impairment of Daily Function | | | | | ≥ 50% | X
Neurological/Neurocognitive | Muscle Weakness | | | X | | X^‡^
Neurological/Neurocognitive | Muscle Pain | | X | | X\|\| | X^‡^ | | X^§^ | X^§^
Neurological/Neurocognitive | PEM | X | X | X | X | X^‡^ | | X^§^ | X^§^
Neurological/Neurocognitive | New Headaches | | X | | | X^‡^ | | X^§^ | X^§^
Neurological/Neurocognitive | Arthralgias (migratory) | | X | X | X\|\| | X^‡^ | | X^§^ | X^§^
Neurological/Neurocognitive | Sleep Disturbances | X^¶^ | X | X | X\|\| | X^‡^ | | X^§^ | X^§^
Neurological/Neurocognitive | Neurological or Neuropsychiatric complaints | X^¶^ | X^**^ | | X\|\| | X^‡^
Neurological/Neurocognitive | Memory or Cognitive Impairment | X^¶^ | X^**^ | X^††^ | X\|\| | | X | X^§^
Neurological/Neurocognitive | Dysequilibrium | X
Neurological/Neurocognitive | Temperature Dysregulation | | | | X^‡‡^
Neuroendocrine/Immune | Autonomic Dysfunction | | X^§§^ | X^§§^
Neuroendocrine/Immune | Fever or Chills | | | | | X^‡^
Neuroendocrine/Immune | Sore Throat | | | | | X^‡^ | | X^§^ | X^§^
Neuroendocrine/Immune | Lymph Node Pain | | | | | X^‡^ | | X^§^ | X^§^
Neuroendocrine/Immune | Neuroendocrine Dysfunction | | X^§§^ | X^§§^ | X\|\|\|\|
Neuroendocrine/Immune | Immune Manifestations | | X^§§^ | X^§§^
Other System Involvement | Cardiovascular Impairment | | | | X^‡‡^
Other System Involvement | Pulmonary Impairment | | | | X^‡‡^
Other System Involvement | Gastrointestinal Impairment | | | | X\|\|\|\|
Other System Involvement | Genitourinary Impairment | | | | X\|\|\|\|

Abbreviations: CDC=Centers for Disease Control and Prevention; CFS= chronic fatigue syndrome; ME= myalgic encephalomyelitis; PEM=post-exertional malaise.

* Defined functional impairment by 36-item Short Form Survey scores, fatigue by Multidimensional Fatigue Inventory, and symptoms by Symptom Inventory Case Definition subscale;

† Onset may be gradual;

‡ 8 of 11 minor symptoms;

§ ≥ 4 symptoms present concurrently for ≥6 months;

|| ≥1 from 3 of the 4 symptom categories (neurocognitive, pain, sleep, neurosensory/motor);

¶ ≥1 of 3 symptoms;

** ≥2 neurological/cognitive manifestations;

†† ≥2 cognitive manifestations;

‡‡ ≥1 energy production/transportation impairment (cardiovascular, pulmonary, thermostatic, temperature);

§§ ≥1 symptoms from 2 of the categories of autonomic, neuroendocrine and immune manifestations;

|||| ≥1 symptoms for ≥3 categories of immune, gastrointestinal and genitourinary impairments

## Key Question 1a What are the accuracy and concordance of methods used to diagnose ME/CFS?

### Key Points

- Diagnostic studies of ME/CFS are limited by the lack of an accepted reference standard (case definition) or an agreed upon set of clinical criteria.
- Concordance was assessed in seven studies reporting variations in symptom prevalence in populations that are defined by different case definitions. Three studies evaluated case definitions by comparing ME/CFS patients with other populations.
- Patients identified by clinical criteria labeled as ME or ME/CFS had more severe symptoms or more functional impairment than those identified by clinical criteria labeled as CFS. Patients with ME or ME/CFS had more severe symptoms than healthy control patients and some groups of patients with other chronic diseases.
- Accuracy, sensitivity, and specificity of clinical criteria for the diagnosis of ME/CFS were assessed in 11 studies; none provided evidence that a single set of clinical criteria is better than other criteria at differentiating ME/CFS from other conditions that may also present with fatigue however the Oxford (Sharpe, 1991) case definition has not been formally compared with other case definitions nor evaluated for diagnostic accuracy or concordance.
- Three studies, one good- and two fair-quality, found that computerized modeling can have good sensitivity and specificity for identification of patients who meet one of the ME/CFS case definitions when compared with healthy controls. These have not been tested in a clinical setting or in patients with diagnostic uncertainty.

### Detailed Synthesis

Evaluation of accuracy of a diagnostic test generally requires an accepted diagnostic reference standard (“gold standard”). Diagnostic studies of ME/CFS are limited by the lack of a single accepted reference standard. The use of clinical criteria is the accepted approach to diagnosis, however as noted above in Table 1 there are multiple case definitions in use. This is an ongoing challenge in terms of evaluating diagnostic tests because studies have used various case definitions as the reference standard against which they measure the utility of a diagnostic test. We evaluated whether these case definitions identify similar or different groups of people; our findings are discussed below.

#### Studies Comparing Case Definitions for ME/CFS

Eight studies evaluated the concordance of different diagnostic criteria (Table G1 of Appendix G).5,9,50–55 One study considered the comparison based on age variance and will be discussed under Key Question 1b.53 These studies examined patients who met the clinical criteria for various case definitions and reported on differences in symptom prevalence between patient populations. These were primarily observational cohort studies and descriptive studies, therefore not amenable to quality rating. Differences reported here are those that were statistically significant between groups (see Table G1 for a complete report).

Studies consistently demonstrate that symptom reporting varies between populations defined by different clinical criteria. In general, populations defined by ME or ME/CFS criteria were more symptomatic and impaired than those defined by CFS criteria.5,9,50–56

Sore throat and lymph node pain were more common in 14 subjects who met the Holmes, 1988 CDC criteria compared with those meeting the Fukuda, 1994 CDC criteria (n=18) and with fatigued patients due to psychiatric illness (n=33).50 This study also compared the 36-item Short Form Survey (SF-36) measurements among these groups and found no consistent differences in terms of bodily pain, general health, physical health composite score, mental health composite score, and self-reported degree of impairment (see Table G1 for details). A similar study compared symptom prevalence for CFS identified by CDC (Fukuda, 1994) criteria with ME/CFS identified by Canadian (Carruthers, 2003) criteria using data from three populations and comparing scores on the DePaul Symptom Questionnaire and the SF-36.^5^ The SF-36 scores indicated significantly less impairment for the CFS group compared with the ME/CFS group in all three populations on the subscales of physical functioning and bodily pain. Symptom reporting indicated less impairment in the CFS group compared with the ME/CFS group in the majority of PEM, pain, autonomic, and immune symptom subcategories. Responses to other symptom subcategories were less consistent across the populations: 4 of 13 neurocognitive symptoms were significantly lower in the CFS group compared with the ME/CFS group for all three populations, and the other seven neurocognitive symptoms were significantly lower in the CFS group compared with the ME/CFS group in just two of the populations (DePaul sample and BioBank). Likewise, only one of six sleep symptoms was lower for CFS compared with ME/CFS in all three populations, whereas three of six sleep symptoms were lower in two of the populations. This may reflect differences in the populations—the DePaul and BioBank demonstrated more consistent differences in symptoms for CFS compared with ME/CFS, whereas the Newcastle sample (those referred by primary care for suspected CFS) did not demonstrate as many differences between those who were identified as having CFS by the CDC (Fukuda, 1994) criteria and those identified as having ME/CFS by the Canadian (Carruthers, 2003) criteria.5

SF-36 and symptom scales were compared among 74 patients who had been labeled as CFS defined by CDC (Fukuda, 1994) criteria with 39 patients labeled as ME defined by the international consensus criteria (Carruthers, 2011).51 In this study, SF-36 subscale scores indicated less impairment among the CFS group versus the ME group on the physical functioning, bodily pain, vitality, and social functioning subscales. Symptom ratings also indicated less impairment among the CFS group compared with the ME group for PEM, neurological, and pain symptoms.

Using a similar population, another study compared the Canadian (Carruthers, 2003) criteria with the CDC (Fukuda, 1994) criteria and an ME definition created from multiple sources, based on the cardinal features of ME (acute onset plus PEM, neurological manifestations, and autonomic manifestations).9 Of the 114 people who met the CDC (Fukuda, 1994) criteria, 56 were also classified as ME/CFS and 27 as ME. There were significant differences among these groups in multiple symptoms; symptom reporting was lower for the group who met CDC (Fukuda, 1994) criteria (but not ME) versus those who met the ME/CFS Canadian (Carruthers, 2011) criteria, and lower for those who met the CDC (Fukuda, 1994) criteria (but not the ME/CFS criteria) versus those who met the ME criteria (defined in this study and based on prior definitions and cardinal features). The ME/CFS group had higher psychiatric comorbidity rates compared with the CFS group. Objective measures of heart rate, cognitive function (trail making tests), and the Kroenke 13 symptom inventory were also compared across groups, demonstrating that ME and ME/CFS groups had higher heart rates lying down and 2 and 10 minutes after standing compared with the CFS-only group, longer times on the trail making tests, and higher scores on the Kroenke symptom and psychiatry comorbidity scale. These findings were consistent with those of two other studies.54,55

Another study compared 41 patients meeting CDC (Fukuda, 1994) criteria with 26 patients meeting London ME (Dowsett, 1994) criteria using the SF-36, Multidimensional Fatigue Inventory 20-item (MFI-20), Karnofsky Performance Scale (KPS), and exercise testing. CFS patients had lower functioning than ME patients on the role-emotional and mental health subscales of the SF-36 (other subscales of the SF-36 were not significantly different between the two groups). The general fatigue score of the MFI-20 was significantly higher for CFS versus ME but the other four components of the MFI-20 were not different. There were no meaningful differences in treadmill exercise test variables for ME subjects versus CFS (5 of the 7 variables were not significant); age predicted hazard ratio (HR) and oxygen consumption (VO_2_) were both higher for the ME group compared with the CFS group (p=0.049).52

In summary, most studies that compared patients meeting case definitions of ME or ME/CFS with patients meeting case definitions of CFS showed that patients diagnosed using an ME or ME/CFS case definition reported worse symptoms and had more impairment in physical and cognitive domains than patients being diagnosed using the CFS case definition. One study comparing patients diagnosed with the London ME (Dowsett, 1994) criteria with the CDC (Fukuda, 1994) criteria found few differences between the two groups; but where there were differences, the CFS patients had worse symptoms than ME patients. Both studies comparing ME with CFS or ME/CFS are small. In the larger studies that compare ME/CFS with CFS there seems to be a consistent finding of more significant differences, favoring the theory that ME/CFS and CFS identify different populations. It may be that the CFS criteria capture a broader population (such that ME and ME/CFS are subsets of CFS), or that ME and ME/CFS identify separate groups entirely.

#### Studies Comparing Symptoms Among ME/CFS and Non-ME/CFS Populations

Three studies compared symptoms of CFS patients diagnosed with the CDC (Fukuda, 1994) criteria with other groups of patients: controls that were healthy and nonfatigued, controls that were fatigued but did not meet CFS criteria, and controls with fatigue and another chronic illness (Table G1).57–59 Although not technically measuring concordance between case definitions, these studies identified scales that distinguished patients meeting criteria for one of the case definitions versus those who did not meet criteria for that case definition. These studies demonstrated significant differences in reported symptoms between patient groups. Differences were measured by the Fatigue Impact Scale (FIS), Chalder Fatigue Scale, Hospital Anxiety and Depression Scale depression subscale (HADS-D), and certain SF-36 subscales or combinations of SF-36 variables with the Zung Self-Rating Depression Scale. These scales may help to identify CFS patients, but they will need to be evaluated in a broad spectrum of patients with diagnostic uncertainty to determine their ability to differentiate between conditions and/or identify clinical subgroups of patients57–59 (see Appendix J for more details).

Variables from the SF-36 and Zung Self-Rating Depression Scale were used to distinguish between 51 women with CFS, 55 with idiopathic chronic fatigue (defined as chronic fatigue not meeting criteria for CFS), and 53 nonfatigued controls matched to the CFS subjects.57 In this study, computer modeling using latent class analysis was able to empirically derive a solution that was comparable with the established case definition. Thus, the computer modeling validated the ability of the CDC (Fukuda, 1994) criteria to differentiate a group of CFS patients from a group of non-CFS patients.

Differences were found in symptom reporting in a study comparing 19 consecutive patients presenting to an academic medical center’s chronic fatigue clinic who met CDC (Fukuda, 1994) criteria with 31 subjects with rheumatoid arthritis (RA).58 General Health Questionnaire scores were highest for the CFS group and lowest for the RA group; the SF-36 role function scores indicated lowest impairment in the RA group and highest in the CFS group; SF-36 mental function was best in the RA group and lowest in the CFS group; SF-36 health perception was highest in the RA group and lowest in the CFS group; no differences in the other SF-36 subscales or in the Modified Symptoms Perception Questionnaire or the Pennebaker Inventory of Limbic Languidness.58

Functional status and well-being were evaluated in 223 patients who met criteria for CFS using the CDC (Holmes, 1988) criteria with both a population-based control sample and a group with various chronic diseases using the SF-36.^59^ CFS patients had lower functioning than the general population on all SF-36 subscales, and lower functioning than almost all disease groups on most subscales: the exceptions were that the CFS group did not differ from the group of 25 multiple sclerosis patients in terms of physical functioning, vitality, and role-emotional, nor did the CFS group differ from the congestive heart failure group on the role-emotional subscale.

Based on these three studies, symptom reporting varies between CFS patients and other populations but the utility of these symptom-based scales in differentiating patients with diagnostic uncertainty remains inconclusive.

##### Accuracy of Measures Used To Diagnose ME/CFS as Defined by Any of the CFS Case Definitions

Eleven cross-sectional and longitudinal studies with comparison groups evaluated methods currently used to diagnose ME/CFS. Two studies evaluated how well symptom scales could predict a subset of patients who fail to recover from cardiopulmonary exercise testing (CPET) and will be discussed under Key Question 1b.60,61 All of these studies provided data on discriminative value (receiver operating curve [ROC], area under the curve [AUC]), sensitivity/specificity, or concordance of diagnoses (Table G2).56,60–69 One study was good-quality,63 seven fair-quality,56,60,61,64–69 and one poor-quality62 (Table H1 of Appendix H). The studies were conducted in the United States56,60,61,65 and western Europe,62–64,66–68 were generally small (range: 25 to 798 participants, with only two studies enrolling >200 participants) and predominately enrolled women (43 to 100% female when reported). Several studies used the same or very similar study populations to report on different outcomes, recruiting from CFS self-help groups,66–68 or a community sample outside Chicago.56,65

Overall the identified studies lacked robustness needed for rigorous evaluation of diagnostic tests for ME/CFS. Major limitations of these studies include: enrolling fewer than 50 total subjects,60–62,66–68 recruitment from specialty clinics,60,61,63 lack of clear blinding to the reference standard result,56,60–68 and comparing cases with either healthy or nonfatigued controls. The use of healthy controls and the case-control design are problematic for diagnostic test studies; ideally, a diagnostic test is able to differentiate patients with the disease from those without in a population of patients with diagnostic uncertainty. Thus, a robust evaluation of a diagnostic test requires a broad spectrum of patients and includes patients who would be reasonable candidates for the test—in this case, patients presenting with fatigue and other symptoms that suggest a diagnosis of ME/CFS. Only one study used a population with overlapping symptoms and tested a strategy for diagnosis in both a derivation and a validation cohort.63

###### Biomarkers as Diagnostic Tests

Four studies evaluated the ability of serum parameters to identify CFS (using the CDC [Fukuda, 1994] and Oxford [Sharpe, 1991] criteria) versus healthy controls, and reported on the AUC for the ROC curve for these measures. The tests included hypothalamic-pituitary axis testing (cortisol response to dexamethasone suppression test),67 insulin tolerance testing and adrenocorticotropic hormone (ACTH), plasma and salivary cortisol responses to insulin injection,66 pro-inflammatory cytokine response to standardized psychological stress,68 and RNase L-isoforms.62 All of the biomarker studies were small (sample size range: 25 to 42). 62,66–68 Three were fair-quality and utilized the same CFS self-help group population in Germany, and one was poor-quality.

Three of the biomarker studies from the same group of investigators66–68 found that biochemical responses to stimuli were abnormal in the ME/CFS group compared with healthy controls. The morning plasma and salivary cortisol responses to low-dose overnight dexamethasone suppression testing were significantly lower in the ME/CFS group versus controls (F=12.16, p=0.003 for morning cortisol and F=11.51, p=0.001 for salivary free cortisol); this finding was consistent when comparing the logAUC (total) between groups.67 The AUC of ACTH response to insulin tolerance testing was significantly associated with reported duration of symptoms (F=4.92, p=0.03), but there were no differences between ME/CFS patients and controls for plasma total and salivary free cortisol (F=0.73, p=0.4; F=2.12, p=0.15).66 Response to stress was tested using the Trier Social Stress Test (TSST), a standardized psychological stress test, and found an inverted pro-inflammatory cytokine response for ME/CFS subjects compared with controls; ME/CFS subjects’ levels of IL-6 and TNF-α decreased at 10 minutes and returned to normal by 60 minutes, whereas the IL-6 and TNF-α levels for controls increased at 10 minutes and returned to normal at 60 minutes (IL-6 F=3.93, p=0.03; TNF-α F=4.64, p=0.02).68 ACTH response also varied between the groups, but cortisol did not (AUC for ACTH response curve F=6.34, p=0.02; AUC for plasma cortisol F=0.1, p=0.91; AUC for salivary cortisol F=1.03, p=0.32).68 These three studies recruited from a CFS self-help group population in Germany and utilized essentially the same patients for all three studies. Although the CFS diagnosis was confirmed subsequently by physician examination or interview, the recruitment process of these studies has potential to provide a limited spectrum of patients with CFS. In addition, because they utilize the same population, these three studies are not independent of each other.66–68

The fourth of these biochemical studies evaluated the sensitivity and specificity of RNase L levels in peripheral blood mononuclear cells for discrimination of ME/CFS subjects from controls. The ratio of RNase L isoforms at a cutoff of 0.4 had a sensitivity of 0.91 and specificity of 0.71; other thresholds resulted in lower sensitivity and specificity.62 Although these tests were able to distinguish between healthy controls, their usefulness remains uncertain without testing in a broader spectrum of patients including those with overlapping features.

###### Self-Reported Symptom Scales as Diagnostic Tests

Three studies created new assessment tools.63,64,69 One good-quality study evaluated an appropriately broad spectrum of subjects, including 41 with systemic lupus erythematosis, 58 with fibromyalgia, and 99 with CFS as defined by Oxford (Sharpe, 1991) criteria; subjects were randomly assigned to either a derivation or validation cohort.63 A new tool was developed by administering prospectively defined criteria via questionnaire; each symptom was assessed for sensitivity and specificity and the symptoms with the best sensitivity and specificity were elected to contribute to the new criteria. Four methods for classification of ME/CFS were tested using the derivation cohort, and for each algorithm sensitivity, specificity, and accuracy were determined using the validation cohort. One of the four strategies that included 24 symptoms, the artificial neural network, had the best results (sensitivity 0.95; specificity 0.85 and accuracy 0.90).63 One other large (n=368 CFS patients diagnosed by a combination of methods including physician interview about the confidence of their diagnosis and 430 controls) fair-quality study tested the Schedule of Fatigue and Anergia for CFS scale in ME/CFS patients and healthy controls using latent class analysis; this study demonstrated good sensitivity (0.81) and specificity (0.98).64 A third fair-quality large (n=691) study used K-means clustering to identify the most predictive symptoms from the DePaul Symptom Questionnaire (DSQ), define thresholds for symptoms, and then calculate sensitivity, specificity, and accuracy for each symptom comparing three definitions of CFS: CDC-CFS (Fukuda, 1991), Canadian, ME/CFS (Carruthers, 2003), and International-ME (Carruthers, 2011). The study authors concluded that the DSQ can provide an accurate basis for diagnosing CFS as compared with these three case definitions and that some high yield symptoms may enhance the predictive capacity of CFS, specifically symptoms that reflect fatigue, general pain, PEM, sleep dysfunction, and neurocognitive issues.69 These findings have not been replicated in other populations.

Three small, fair-quality studies that reported on cortisol testing also reported the AUC values for the MFI-20, Hospital Anxiety and Depression Scale (HADS), the Symptom Checklist 90, Revised (SCL-90-R), and the Sickness Impact Profile 8-item (SIP-8), using essentially the same patient population; these studies found that all measures were significantly different between CFS cases (CDC (Fukuda, 1994) and Oxford (Sharpe, 1991)) and healthy controls (no medications, no current/lifetime psychiatric symptoms or disorders).66–68 While AUCs were different, these studies do not further the diagnostic strategy for ME/CFS because of their methodological limitations: small sample size, case-control design, unclear recruitment methods, and unclear reporting of attrition and blinding (Table H1). These results show that patients with ME/CFS have more depression, anxiety, and decreased functionality in several other domains; but because the comparison population consisted of healthy controls there is no evidence that these tests could adequately distinguish a ME/CFS population from another population of depressed, anxious, or medically ill patients. Overall, it is unclear whether these measures could diagnose ME/CFS if used by themselves (in the absence of the clinical criteria), because alone these measures do not satisfy the multiple symptom domains that currently comprise the syndrome of ME/CFS.

Two studies evaluated the ability of existing symptom scales to identify ME/CFS patients or to correlate with specific aspects of the diagnostic criteria such as disability or fatigue, in hopes of providing a more standard assessment tool for use in diagnosing ME/CFS. A fair-quality small study (24 ME/CFS patients and 84 healthy controls) evaluated the SF-36, the CDC Symptom Inventory, and the MFI-20 for identifying ME/CFS subjects who met the disability criterion for the CDC (Reeves, 2005) criteria.49 The MFI-20 had reasonable sensitivity (0.95) for the criteria but poor specificity (0.27); none of the AUCs for the MFI-20 were above 0.90.^56^ In this study, the CDC Symptoms Inventory had poor sensitivity and specificity, as did the SF-36 subscales of physical functioning, role physical, social functioning, and role-emotional (none with AUC, sensitivity, or specificity above 0.90).56

In a subsequent paper, also fair-quality, the SF-36 was further evaluated using two different ME/CFS populations: 32 CFS patients recruited from the community and 114 CFS patients recruited from tertiary care defined by CDC (Fukuda, 1994) criteria, as well as 47 nonfatigued controls. Similar to the previous findings, none of the AUCs for the community-based CFS patients were above 0.90, whereas three AUCs for subscales of the SF-36 in the tertiary care CFS population were close to or above 0.90 (vitality, role-physical, and general health all had AUC of 0.91; social functioning had AUC of 0.87). Additional analysis focused on vitality, role-physical, and social functioning to determine cutoffs and assess whether the use of combinations of scales could identify ME/CFS subjects in both the community and the tertiary care samples as distinguished from healthy controls. The study authors determined that meeting the cutoffs for two or more of these three subscales could be used to designate substantial reductions in function and to potentially distinguish those with ME/CFS from those without ME/CFS. For the community-based ME/CFS sample, sensitivity was 0.93 and specificity was 0.75; for the tertiary care sample, sensitivity was 0.96 and specificity was 0.75.^65^ These researchers also used the MFI-20, the CDC Symptom Inventory, and the SF-36 to assess the sensitivity and specificity of the CDC-CFS (Reeves, 2005) criteria for identifying CFS in the community population compared with healthy controls; the AUC for Reeves criteria was 0.70 (sensitivity 0.65; specificity 0.76).65 These studies do not appear to contribute to operationalizing the ME/CFS criteria given the inconsistencies in the results. The subscales of the SF-36 show promising results in a tertiary care, recruited population (the SF-36 scores for vitality, role-physical, and general health were above 0.90);56 however, this was not true for the community-recruited ME/CFS patients.

## Key Question 1b How does the use of these methods vary by patient subgroups?

### Key Points

- One study reported that older patients were more impaired, but it did not consider how symptom evaluation might vary with age.
- Two studies found that CPETs were different between ME/CFS patients and healthy controls, and that certain subscales of the SF-36 were associated with slow recovery after exercise. No studies evaluated differences in the performance of case definitions among patients with specific symptom sets (autonomic/neuroendocrine, neurological/neurocognitive, or presumed infectious etiologies).

### Detailed Synthesis

Three studies evaluated potential diagnostic tests in subgroups of ME/CFS patients.53,60,61 Using a unique approach, one study evaluated whether symptoms vary for younger versus older CFS patients. They studied 50 CFS patients, diagnosed using the CDC (Fukuda, 1994) criteria, matching 25 older subjects (>50 years) by sex and duration of CFS diagnosis with 25 subjects aged 16 to 29 years.53 Older CFS patients were more impaired, having higher FIS scores, higher Chalder Fatigue scores, higher HADS-D scores, lower functioning by SF-36, and lower self-efficacy. The two groups did not differ on the Cognitive Failures Questionnaire, HADS total, HADS anxiety subscale (HADS-A), pain rating, Epworth Sleepiness Scale, and Orthostatic Grading Scale. Several autonomic and hemodynamic measures differed between older and younger CFS patients: older patients had lower resting heart rates, higher left ventricular ejection time, lower baroreflex sensitivity (ability to maintain blood pressure) than younger patients, but there were no differences in systolic, diastolic, or mean blood pressure, total heart rate variability during a supine 10 minute rest, baroreflex effective index, and systolic blood pressure with active stand.

Diagnostic tests to predict recovery from exercise testing were evaluated in two fair-quality studies of the same population.60,61 The first of these studies demonstrated that CPET capacity was significantly different between CFS patients defined by CDC (Fukuda, 1994) criteria and nondisabled sedentary controls. SF-36 and MFI-20 were then tested to determine whether these two scales could distinguish those who would fail to recover from testing within 1 day. The AUC analysis demonstrated that SF-36 subscales of physical function, role-physical, bodily pain, general health, vitality, and social functioning were significant for failure to recover at 1 day; and the subscales role-emotional, vitality, and bodily pain were significant for failure to recover at 1 week.60 A separate study evaluated whether individual symptoms could identify CFS patients defined by CDC (Fukuda, 1994) criteria versus controls and found that the symptoms of fatigue, neuroendocrine dysfunction, immune dysfunction, pain, and sleep disturbance all had significant AUC, whereas muscle stiffness, autonomic, and “other” symptoms were not significant.61 These studies are limited by small size and case-control design and preclude any valid conclusion about the utility of SF-36 or MFI-20 for prediction of failure to recover at 1 day or 1 week.

## Key Question 1c What harms are associated with diagnosing ME/CFS?

### Key Points

- Fourteen studies evaluated consequences of the diagnostic process or diagnosis of ME/CFS.
- Five studies found that patients with ME/CFS feel stigmatized by their diagnosis in terms of financial stability, work opportunities, perceived judgments on their character, social isolation, and interactions with the health care system.
- Prejudice and stereotypes within the medical profession were identified in two studies; medical trainees and mental health practitioners make judgments about a patient’s condition based on the name it carries (ME, CFS, or other) and what treatment is being given.
- One study described patients’ fear, anxiety, confusion, self-doubt, and bitterness when they lacked a diagnosis for their problems, as well as their feelings of both social and medical legitimacy upon obtaining a diagnosis.
- Six studies describe a substantial burden of misdiagnosis among the CFS population.

### Detailed Synthesis

Consequences of the diagnostic process or the diagnosis of ME/CFS were evaluated in 14 studies that used primarily descriptive methods not amenable to quality rating (Table G3).14,21,70–81 Studies used a variety of methods to assess patients’ experiences and understanding of their disease including qualitative interviews, surveys, and an internet discussion group. Verification of registry referral criteria, review of specialty clinic referral rejections by chart review, and interviews of providers were used to assess misdiagnosis and provider perceptions of diagnosis. One study performed thorough psychiatric evaluation to identify the frequency of missed psychiatric disease in CFS.73 Two studies randomized participants to various disease names but with identical case descriptions in order to test the effect of the disease name on perceptions by medical trainees and undergraduate students.14,70

The five studies that used either survey or interview methods to assess harms found that ME/CFS patients experience social stigma as a result of their disease. These include decrease in financial stability (lower standard of living in 92 of 207 patients, new job that required fewer skills or pay cut in 30 to 35 of 207 patients), decrease in social life (174 of 207 patients) and loss of friends, (79 of 207 patients) feeling estranged (42 of 45 patients), decrease in recreational activities (186 of 207 patients), feeling like they needed to conceal their symptoms (17 of 44 patients), delegitimization (10 of 14 patients) and difficult interactions with the medical profession (stereotypes perpetuated and doctors having decided before meeting them that they had a psychological diagnosis), and feeling like their moral character was questioned.71,72,74–76 A separate study described patients’ fear, anxiety, confusion, self-doubt, and bitterness when they lacked a diagnosis for their problems, as well as their feelings of both social and medical legitimacy upon obtaining a diagnosis.81 In this study, 45 of 50 people interviewed reported that diagnosis was the single most helpful event in the course of their illness.

Two publications describe a study of undergraduate students (n=105) and medical trainees (n=141) who were randomized to being told that the diagnosis for a patient case presentation (identical among all groups) was either CFS, ME, or Florence Nightingale Disease.14,70 Medical trainees’ perceptions of diagnostic accuracy, physiological etiology, and prognosis varied between groups; CFS label was considered most accurate, while the ME label carried worse prognosis. Mental health practitioners were randomized to being told that an identical CFS patient was getting one of three treatments. The assigned treatment appeared to influence subsequent attributions of the patient’s disease. Specifically, practitioners who were told that the patient was getting an intravenous immune modulator as the treatment were more likely to think that the patient was correctly diagnosed as having CFS and was more disabled (p<0.05 for both).70

Attempting to understand the possible benefits conferred by a diagnosis, one group surveyed 20 general practitioners and 50 patients with CFS. Providers reported feeling reluctant to diagnosis CFS because of uncertainty about the impact of a diagnosis on the patient, complexity of offering care, and concern that the diagnosis might become a self-fulfilling prophecy. Meanwhile, patients described fear, anxiety, confusion, self-doubt, and bitterness when they lacked a diagnosis for their problems, followed by a feeling of both social and medical legitimacy upon obtaining a diagnosis. While it did not diminish the severity of symptoms, getting a diagnosis seemed to positively influence the way the patients managed their symptoms.81

Missed diagnoses, whether exclusionary or concomitant (such as psychiatric), are common among patients being evaluated for ME/CFS. A prospective evaluation of the frequency of misdiagnosis in patients with CFS studied 68 patients who met the Oxford (Sharpe, 1991) criteria. Patients participated in a standardized structured interviews with a consultant psychiatrist, and a full medical, psychiatric, family, and personal history was obtained. Of 68 patients evaluated, 31 (46%) reported having been given a psychiatric diagnosis (2 out of 3 of them had been incorrectly diagnosed).73 Specifically, 21 patients had been given a psychiatric diagnosis when one did not exist, and 13 patients who had never been given a psychiatric diagnosis actually had a treatable psychiatric condition in addition to CFS.73

Likewise, a case series of 135 patients who were enrolled in the PACE trial using the Oxford (Sharpe, 1991) criteria, reported that 76 patients (56%) had psychiatric co-morbidity.79 Indeed, the prevalence of alternate diagnoses in people for whom a diagnosis of CFS is being considered has been well-described. Among those with a preliminary diagnosis of CFS, over half had at least one exclusionary diagnosis.21,77 Among patients referred to the Newcastle CFS Clinical Service and meeting CDC (Fukuda, 1994) criteria, three clinical phenotypes emerged: 3 percent had positional orthostatic tachycardia syndrome (POTS), 3 percent had a CFS/fibromyalgia overlap phenotype, and 20 percent had symptoms precipitated by a viral/bacterial infection. In this study, those who were referred but did not meet the CDC (Fukuda, 1994) criteria had the following alternative diagnoses: chronic disease (47%), sleep disorders (20%), psychological disorders (15%), idiopathic disorders (13%), cardiovascular disorders (4%), and other disorders (1%).80 Of 418 referrals to a specialty CFS clinic in London, 52 (26%) had a likely alternative psychiatric diagnosis and 67 (35%) had a likely alternative medical diagnosis.78

## Key Question 2 What are the (a) benefits and (b) harms of therapeutic interventions for patients with ME/CFS, and how do they vary by patient subgroups?

### Key Points

- Thirty-five trials provided evidence of benefits and harms of treatment; all were small, most had methods rated as poor- or fair-quality, and comparisons across trials were limited by dissimilar outcome measures.

#### Medications

- Nine trials met inclusion criteria for medical treatment of ME/CFS, although none of the medications have been approved by the U.S. Food and Drug Administration (FDA) for this indication.
- Two fair-quality trials of rintatolimod, an immune modulator not currently approved for use in the United States, enrolled severely debilitated participants and found improvement in measures of exercise performance (low strength evidence). Improvement in other measures of function and reduction of use in other medications for relief of CFS symptoms was also found in one of the studies, but evidence was insufficient to draw conclusions.
- A small fair-quality trial of valganciclovir enrolled patients with suspected viral onset of ME/CFS and elevated antibody titers and reported improved fatigue compared with placebo based on one scale, no differences for other outcome measures, this study will need to be replicated to provide adequate proof of efficacy.
- Small single trials of isoprinosine, hydrocortisone, immunoglobulin G, and fluoxetine did not show significant improvement compared with placebo. Differences were also not found in a larger dose-ranging trial of galantamine. These studies provided insufficient evidence of treatment effects.
- Additional trials with durations less than 12 weeks indicated no differences with placebo for acyclovir, and improved scores for physical health and function with rituximab, although both studies enrolled 30 or fewer participants and the clinical implications of these results are not clear.
- Harms of medications included suppression of adrenal glucocorticoid responsiveness, increased appetite, weight gain, and difficulty sleeping with hydrocortisone; flu-like syndrome, chills, vasodilatation, dyspnea, and dry skin with rintatolimod; headaches with immunoglobulin G; and nephrotoxicity with acyclovir. Withdrawals due to harms were greater with fluoxetine than placebo.

#### Complementary and Alternative Medicine

- Seven trials compared one CAM approach with usual care, placebo, or alternative CAM intervention. Interventions included dietary supplements (insulin-like growth factor, antioxidant, acetyl-carnitine), distant healing, homeopathy, melatonin, and phototherapy.

All outcomes studied have insufficient evidence due to small single studies with methodological limitations.

- Trials of CAM interventions found no clinically or statistically significant improvements compared with placebo, usual care, or an alternative CAM approach.
- Three small fair-quality trials of CAM interventions (one with homeopathy, one with pollen extracts, and one with L-carnitine preparations) found improvement from baseline in some measure of fatigue and/or function or well-being but not others.
- One good-quality study found that being aware that one is not receiving distant healing resulted in smaller improvements in function.
- Adherence was low in one trial of a low sugar/low yeast diet but otherwise adherence and harms were not well reported.

#### Counseling and Behavior Therapies

- Fourteen trials (23 publications) comparing one counseling or behavioral therapy with usual care, wait list control, no treatment, relaxation techniques only, adaptive pacing, anaerobic therapy, graded exercise treatment (GET), or an alternate form of counseling or behavioral therapy were included.
- When considering all studies comparing any type of counseling with no treatment, support, relaxation, or adaptive pacing there is low strength of evidence that counseling decreases fatigue (7 of 11 trials showed positive effect), low strength of evidence for improvement in measures of functioning (4 of 11 trials showed positive effect; 2 of 11 showed mixed results on different measures), low strength of evidence for improvement in quality of life (2 of 4 trials showed positive effect), and moderate strength of evidence for global improvement (2 of 2 trials showed positive effect).
- Low strength of evidence suggests that at followup, patients receiving counseling had better SF-36 physical functioning subscale scores than control patients, based on a pooled analysis of eight trials; weighted mean difference score of 7.73 (95% confidence interval [CI], 3.58 to 11.87). However, when results were limited to the four studies that used CBT specific techniques the results were similar but no longer statistically significant.
- There is low strength of evidence from a small fair-quality trial that face-to-face counseling is similar to telephone counseling in improving function, employment measures, and global change.
- Harms of counseling and behavioral therapies were poorly reported but there is low strength of evidence that counseling is not associated with harms, based on one moderate-sized and one large-sized trial.

#### Exercise Therapy

- Six trials (7 publications) provided evidence on the effectiveness and harms of exercise therapies.
- GET improved measures of fatigue (low strength of evidence), function (moderate strength of evidence), and clinical global impression of change (moderate strength of evidence); treatment effectiveness may not be generalizable to all patients and may overestimate the benefit as no study used a case definition selecting for more disabled patients.
- Although single small studies found qigong exercise provided improvement in measures of fatigue and that home orthostatic training was similar to usual care or sham orthostatic training, this evidence was insufficient due to small sample sizes and methodological limitations of the studies.
- Harms were not well reported. Although total withdrawal rates were similar to controls in three of four trials, due to the high rate (20%) of patients refusing repeat exercise testing in one study, lack of subgroup analysis throughout, and no studies selecting for a more disabled population (ME case definition), evidence remains insufficient to determine harms of exercise therapies and whether subsets of patients may experience more or fewer harms.

#### Combination Therapy and Head-to-Head Comparisons

- Four trials (8 publications) were included that compared either head-to-head interventions or combinations of two interventions.
- GET and cognitive behavioral therapy (CBT) had similar improvement on measures of function (low strength of evidence). Fatigue measures are also likely similar; however, results are mixed (insufficient evidence).
- Evidence on the comparison of GET and fluoxetine is insufficient because there was only one small study with methodological flaws. This study found GET improved measures of fatigue and function, whereas fluoxetine did not.
- CBT appears to be associated with fewer harms than GET.

### Detailed Synthesis

Thirty-five trials of interventions for patients with ME/CFS in 45 publications met inclusion criteria; 9 trials of medications, 7 of CAM interventions, 14 of counseling and behavior therapies, 6 of exercise therapies, and 4 of either head-to-head comparisons or combinations of these interventions (Table G4). Seven were rated good-quality, while 23 were rated fair- and 5 poor-quality (Table H2).

Trials enrolled from 16 to 641 patients with ME/CFS and most (25 of 35, 71%) used the CDC (Fukuda, 1994) criteria. Outcome measures included the SF-36 physical functioning subscale, Medical Outcome Study Short Form (MOS-SF), Checklist of Individual Strength (CIS), Profile of Mood States (POMS) fatigue subscale, KPS, and SIP-8 scale to measure overall function; MFI-20, Chalder Fatigue Scale, Krupp Fatigue Severity Scale (FSS), FIS, and Visual Analogue Scale (VAS) to measure fatigue; Quality of Life Inventory (QOLI), Quality of Life Index (QLI), Quality of Life Scale (QLS), EuroQol Scale, Global Wellness Scale, Short Form 12-item Health Survey (SF-12), and Fibromyalgia Impact Questionnaire (FIQ) to measure quality of life; Clinical Global Impression Change (CGI) scales to measure improvement over time; and the Work and Social Adjustment Scale to measure impairment in work. These are described in Appendix J.

#### Medications

Nine randomized trials provided evidence for the medical treatment of ME/CFS, including placebo-controlled trials of galantamine,82 hydrocortisone,83 hydrocortisone plus fludrocortisone,84 immunoglobulin G,85 valganciclovir,86 rintatolimod,87,88 isoprinosine,89 and fluoxetine90 (Table 3 below; Table G4). None of these medications have been approved by the FDA for this indication. Two medications are still investigational and not currently FDA approved for any indication, intravenous rintatolimod87,88 and oral isoprinosine.89 Additional trials not meeting inclusion criteria because they had durations less than 12 weeks indicated no differences with placebo for acyclovir,91 and improved SF-36 scores for physical health and function with rituximab.92 Both studies enrolled 30 or fewer participants and the clinical implications of these results are not clear.

Table 3 Trials of medications for ME/CFS

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Overall Effect: Treatment Compared With Placebo
Blacker, et al., 2004^82^ N=423 Fair | CDC (Fukuda, 1994) criteria | 4 months (16 weeks, 8 weeks at full dose) | A. Galantamine 2.5 mg TID B. Galantamine 5 mg TID C. Galantamine 7.5 mg TID D. Galantamine 10 mg TID E Placebo | Fatigue: Chalder Fatigue Scale (mean change from baseline) Physical scores: NS Mental scores: NS Quality of life: FIQ (mean change from baseline): NS Global Well Being (composite): NS Other: % Improvement on modified CGI: NS
Blockmans, et al., 2003^84^ N=80 Fair | CDC (Fukuda, 1994) criteria | 3 month treatment; 3 month placebo crossover | A. Hydrocortisone 5 mg/day + 9-alpha fludrocortisone 50 μg/day B. Placebo | Fatigue: VAS degree of fatigue: NS SFQ score: NS Quality of life: VAS degree of well-being: NS Function: SF-36: NS
Diaz-Mitoma, et al., 2003^89^ N=15 Poor | CDC (Holmes, 1988 and Fukuda, 1994) criteria | 3 months (12 weeks) of treatment | A. Oral Isoprinosine 1 g TID in weeks 1, 3, 5, 7, 9, and 11 only on Monday–Friday; and 1 g/day in weeks 2, 4, 6, 8, 10, and 12 only on Monday–Friday. B. Placebo | Fatigue: KPS (% change from baseline): NS Other: Activities of daily living scale; no differences but data not provided
McKenzie, et al., 1998^83^ N=60–70 varied by outcome Fair | CDC (Holmes, 1988) and Fukuda, 1994) criteria | 3 months (12 weeks) | A. Oral hydrocortisone 20–30 mg every morning and 5 mg every evening B. Placebo | Fatigue: POMS fatigue subscale: NS POMS vigor subscale: NS Quality of life: Global Wellness scale: NS Function: Activity Scale: NS
Montoya, et al., 2013^86^ N=30 Fair | CDC (Fukuda, 1994) criteria | 6 months treatment, 6 months followup | A. Oral valganciclovir 900 mg BID for 21 days, then 900 mg/day for total of 6 months B. Placebo | Fatigue: FSS (change in score, negative indicates better health): −0.06 vs. 0.02; p=0.006 MFI-20: NS Function: Self-reported physical function: NS Other: CDC Symptom Inventory: NS
Peterson, et al., 1990^85^ N=28 Fair | CDC (Holmes, 1988) criteria | 6 months | A. IV IgG (1 g/kg) every 30 days for 6 months (6 infusions) B. Placebo | Function: MOS-SF score for social function higher in placebo group: 5.2 (5.5) vs. 9.4 (7.9); p<0.05 MOS-SF physical: NS
Strayer, et al., 1994^87^ N=76–84 varies by outcome Fair | CDC (Holmes,1988) and Fukuda, 1994) criteria | 6 months | A. IV rintatolimod 200 mg twice weekly 4 times, then 400 mg twice weekly for a total of 24 weeks B. Placebo | Function: Exercise duration (% change from baseline): 10.3 vs. 2.1; p=0.007 Exercise work (% change from baseline): 11.8 vs. 5.8; p=0.011 ADL score (% change from baseline): 23.1 vs. 14.1; p=0.034 KPS score (% change from baseline): +20 vs. 0; p=0.023 Other: Decreased used of medications for relief of CFS symptoms declined for rintatolimod but not placebo
Strayer, et al., 2012^88^ N=240 Fair to good | CDC (Holmes,1988) and Fukuda, 1994) criteria | 10 months (40 weeks) | A. IV rintatolimod 400 mg twice weekly for 40 weeks B. Placebo | Function: Cardiopulmonary exercise tolerance (% change from baseline: 36.5% vs. 15.2%; p=0.047 KPS score, ADLs, Vitality Score (SF-36), and General Health Perception (SF-36) measured pre and post, but not compared between rintatolimod and placebo groups Other: Decreased use of medications for relief of CFS symptoms: 68% vs. 55%; p=0.048
Wearden, et. al 1998^90^ N=68 Fair Same study as on Table 6 and 7 | Oxford (Sharpe, 1991) criteria | 6.5 months | A. Fluoxetine 20 mg/day B. Placebo | Fatigue: Chalder Fatigue Scale (mean change from baseline): NS Chalder Fatigue Scale (non-cases of fatigue with score <4): NS Function: Functional work capacity (mean change): NS

Abbreviations: ADL= Activities of Daily Living; BID=twice a day; CDC= Centers for Disease Control and Prevention; CFS= chronic fatigue syndrome; CGI= Clinical Global Impression change score; FIQ= Fibromyalgia Impact Questionnaire; FSS= Fatigue Severity Scale; g= gram; IgG= immunoglobulin G; IV= intravenous; kg= kilogram; KPS= Karnofsky Performance Scale; MFI-20= Multidimensional Fatigue Inventory; mg= milligram; MOS-SF= Medical Outcome Study Short Form; N= sample size; NS= not significant; POMS= Profile of Mood States; SF-36= 36-item Short Form Survey; SFQ= abbreviated fatigue questionnaire; TID= three times a day; μg= microgram; VAS=visual analogue scale; vs.= versus

Eight trials met criteria for fair-quality,82–88,90 and one for poor (Table H2).89 Major limitations of studies include enrolling fewer than 20 subjects in an arm,85,86,89 high loss to followup,82,90 lack of intention-to-treat analysis of outcomes,84,87 lack of reporting between-group comparisons for key outcomes,88 unclear randomization process,89 and lack of blinding.89 Most trials were either funded by pharmaceutical companies (fully or in part)82,85–88 or the funding source was not reported.83,84

Most trials were designed to treat the potential underlying pathology of ME/CFS. All but two trials89,90 enrolled participants in the United States. Only three enrolled more than 100 participants,82,88,90 and three were multi-center.82,87,88 Participants were predominantly women, and their mean ages ranged from 32 to 50 years. Although most participants were white, many trials did not report race or ethnicity. Most trials used the CDC (Fukuda, 1994) criteria in their inclusion criteria except for one study predating it that used the CDC (Holmes, 1988) criteria,85 and one trial that used the Oxford (Sharpe, 1991) criteria.90 The duration of illness varied widely with some trials enrolling participants with durations under 3 years83,84,89,90 while others were 10 years or more.86,88

Outcome measures of fatigue differed between trials, precluding direct comparisons. These included the CGI scale, Chalder Fatigue Scale, POMS (fatigue and vigor subscales only), VAS (degree of fatigue; abbreviated fatigue questionnaire), FSS, fatigue scale specific to the trial, hours of rest per day, Symptom Severity Scale (fatigue, prolonged post-exertion fatigue), CPET tolerance, exercise duration and work, MFI-20, and CDC CFS Symptom Inventory. Additional measures of function and quality of life were also used as outcomes.

Strength of evidence ratings indicated low strength of evidence for intravenous rintatolimod in improving exercise performance in patients with ME/CFS, because results were based on two trials with differing outcome measures. All other trials found no differences or inconsistent results compared with placebo and were limited by small sizes and methodological limitations, leading to insufficient evidence ratings.

Three trials compared immune modulating drugs with placebo, including trials of intravenous rintatolimod87,88 and oral isoprinosine, both not currently FDA approved for any indication in the United States.89 In an early trial of rintatolimod, 92 severely debilitated patients (KPS scores of 20 to 60) were randomized to rintatolimod 200 mg twice weekly for 4 weeks, then 400 mg twice weekly for a total of 24 weeks, or placebo.87 The median percentage changes from baseline to week 24 were significantly different between groups for exercise duration (10.3 for rintatolimod vs. 2.1 for placebo; p=0.007), exercise work (11.8 for rintatolimod vs. 5.8 for placebo; p=0.011), activities of daily living (23.1 for rintatolimod vs. 14.1 for placebo; p=0.034), and KPS (20 for rintatolimod vs. 0 for placebo; p=0.023). Attrition was 9 percent and adherence 91 percent, and harms did not differ between groups. This trial was limited by lack of intention-to-treat analysis.

A second trial randomized 240 participants (KPS scores of 40 to 60) to rintatolimod 400 mg twice weekly for 40 weeks or placebo.88 The mean percentage change in CPET tolerance from baseline to week 40, the primary outcome, was greater for the treatment versus placebo group (37% vs. 15%; p=0.047). Although other performance scores were measured, they were not compared between groups (KPS, activities of daily living, SF-36 vitality and general health perception subscales). More participants in the treatment group reported decreased use of medications for relief of CFS symptoms (68% vs. 55%; p=0.048). Attrition was 19 percent and adherence 83 percent. Flu-like syndrome, chills, vasodilatation, and dyspnea were more frequent in the treatment group (p<0.05).

A single-blinded trial of isoprinosine randomized 10 patients to treatment and 6 to placebo.89 The treatment group received 3 g/day of isoprinosine in divided doses for 12 weeks that varied over time. Mean changes in KPS scores from baseline did not differ between groups (p=0.93).

A randomized double-blind placebo controlled trial of valganciclovir, an antiviral agent, enrolled 30 participants with suspected viral onset of ME/CFS and elevated antibody titers.86 The treatment group received oral valganciclovir 900 mg twice daily for 21 days, then 900 mg once daily for a total of 6 months. Participants were followed for another 6 months, and outcomes were measured at 9 months. Differences were statistically significant from placebo for scores on the FSS (−0.06 for valganciclovir vs. 0.02 for placebo; p=0.006), but not the MFI-20, CDC CFS Symptom Inventory, or self-reported physical function. Attrition was 9 percent and adherence 91 percent. No harms were reported for either group.

To evaluate the efficacy of galantamine, an acetyl-cholinesterase inhibitor, participants from 35 clinical centers in the United Kingdom, western Europe, and the United States were randomized to oral galantamine at various doses (7.5, 15, 22.5, or 30 mg/day) or placebo for 16 weeks (8 weeks at full dose).82 Outcome measures indicated no statistically significant differences or dose effect between groups for the primary outcome of global improvement (CGI scale), or secondary outcomes of fatigue (Chalder Fatigue Scale) and quality of life (FIQ). The overall withdrawal rate was 23 percent and attrition rate 30 percent, but rates were highest among groups given galantamine doses of 15 mg or more per day. Overall, 90 percent reported harms, with depression, nausea, and headache most common in both groups. Two percent of the galantamine participants experienced serious events, but none was attributed to the study drug.

Two trials evaluated corticosteroids versus placebo, including a trial randomizing 70 participants to oral hydrocortisone (20 to 30 mg every am and 5 mg every pm) or placebo for 12 weeks,83 and a crossover trial of 100 participants using hydrocortisone (5 mg/day) plus 9-alpha fludrocortisone (50 μg/day) for 12 weeks.84 Neither study reported statistically significant differences in outcomes between treatment and placebo groups for fatigue (POMS; VAS), quality of life (Global Wellness scale; VAS), or function (activity scale; SF-36). Attrition rates were 10 percent83 and 20 percent.84 Harms that significantly differed between treatment and placebo groups included suppression of adrenal glucocorticoid responsiveness (12 vs. 0; p<0.001); increased appetite (17 vs. 8; p=0.02); weight gain (19 vs. 8; p=0.006); and difficulty sleeping (17 vs. 8; p=0.02).83

Intravenous immunoglobulin G (1 gm/kg) versus placebo (1% albumen solution) given once every 30 days for 6 months was evaluated in a trial of 30 participants.85 While measures of fatigue, prolonged post-exertion fatigue (Symptom Severity Scale), and physical function (MOS-SF) were not statistically significantly different between groups, social function (MOS-SF) improved for the placebo group (p<0.05). Overall, attrition was 7 percent, and 20 percent experienced harms including 93 percent of treatment and 60 percent of placebo participants reporting headaches (p=0.03).

Fluoxetine was compared with placebo in a 6-month, 4-arm fair-quality trial that also included a GET group which will be described separately below.90 Differences between fluoxetine and placebo were not statistically or clinically significant for fatigue (Chalder Fatigue Scale), functional capacity measured as the amount of oxygen consumed in the final minute of exercise per kg of body weight, or rates of nonfatigue (Chalder Fatigue score of <4) Attrition was higher with fluoxetine than placebo (32% vs. 17%) and adherence was not reported. Withdrawals due to medication side effects were greater with fluoxetine (9 of 68, 13%) than placebo (2 of 68, 3%) although there were no differences in total withdrawals.

Two trials not meeting inclusion criteria because the treatment was less than 12 weeks in duration were examined for completeness. A crossover trial of intravenous acyclovir enrolled 27 adults with CFS who met serologic criteria for Epstein-Barr virus.91 All patients were treated with acyclovir or placebo for 37 days, then they crossed over to the alternate treatment. Fatigue, vigor, and wellness scores, as well as other outcomes, did not differ between groups, although three patients developed acyclovir-induced nephrotoxicity. The second trial randomized 30 patients with CFS to intravenous rituximab, a monoclonal antibody, or placebo given as an infusion at two different times spaced 2 weeks apart.92 More participants in the rituximab compared with placebo group had improved SF-36 physical health and function scores and unadjusted fatigue scores, although adjusted differences were not statistically significant.

In summary, there is low strength evidence that rintatolimod improves measures of exercise performance (improved CPET tolerance 36.5% vs. 15.2%, p=0.047; exercise duration 10.3% vs. 2.1%, p=0.007; exercise work 11.8% vs. 5.8%, p=0.01); and insufficient evidence for other medications because few differences were found between treatment and placebo groups and each was evaluated by only one small trial with important methodological limitations (Appendix K).

#### Complementary and Alternative Medicine Therapies

Seven trials comparing one CAM approach with usual care, placebo, or alternative CAM therapy were included (Table 4 below; Table G4).93–99 Three trials treated potential underlying pathology (insulin-like growth factor, antioxidant, acetyl-carnitine deficiency)94–96 whereas the others targeted perpetuating factors. Two trials met criteria for good-quality methods,95,97 four fair-quality,93,96,98,99 and one poor-quality94 (Table H2). Trials evaluated different dietary approaches or supplements, distant healing, homeopathy, melatonin, and phototherapy. Most were conducted in Europe and all but one97 of the trials had small sample sizes (n<100). Five of the trials enrolled patients based on the CDC (Fukuda, 1994) criteria and two of the trials used the Oxford (Sharpe, 1991) criteria. Major limitations of studies included inadequate or unclear randomization,94,99 enrolling fewer than 20 subjects in an arm,93,94,99 high loss to followup,93 lack of intention-to-treat analysis of outcomes,93,98,99 unclear or inadequate blinding,93,96,99 and dissimilar groups at baseline.95 Trials were either funded by foundations or trusts,97–99 pharmaceutical companies (fully or in part),95,96 or the funding source was not reported.93,94

Table 4 Trials of complementary and alternative medicine therapies for ME/CFS

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Overall Effect Intervention A vs. Intervention B vs. Intervention C, etc.
Hobday, et al., 2008^93^ N=39 Fair | CDC (Fukuda, 1994) criteria | 6 months (24 weeks) | A. Low sugar/low yeast B. Healthy eating | Fatigue outcomes: Chalder Fatigue Scale scores: NS SF-36 vitality subscale scores: NS Function outcomes: SF-36 physical functioning subscale scores: NS
Ockerman, 2000^94^ N=22 Poor | CDC (Fukuda, 1994) criteria | 3 months | A. Pollen: Antioxidant extract of pollen (Polbax) B. Placebo | Fatigue outcomes: Fatigue scores, mean change: 0.43 vs 0.18; p=NR Quality of life outcomes: Total well-being scores, mean change: 1.66 vs 0.21; p=NR Change in total well-being after treatment: p=NR Worse: 9.5% (2/21) vs. 18% (4/22) No change: 29% (6/21) vs. 59% (13/22) Better: 62% (13/21) vs. 23% (5/22))
The, et al., 2007^95^ N=57 Good | CDC (Fukuda, 1994) criteria | 3.5 months (14 weeks) | A. Acclydine B. Placebo | Fatigue outcomes: CIS fatigue severity scores: NS Function outcomes: SIP-8 scores: NS Other outcomes: Physical activity level over a 12-day period: NS
Vermeulen and Scholte, 2004^96^ N=89 Fair | CDC (Fukuda, 1994) criteria | 6 months (24 weeks) | A. Acetyl-L-carnitine (ALC) B. Propionyl-L-carnitine (PLC) C. Combination, Acetyl-L-carnitine 2 g/day + propionyl-L-carnitine 2 g/day (combo) | Fatigue outcomes: General fatigue scores based on MFI-20 scores at 24 weeks, mean (SD): 15.9 (4.2) vs. 16.5 (3.1) vs. 17.3 (3.3); p=NR Other outcomes: % Improved from baseline: CGI at 24 weeks: 59% (17/29) vs. 63% (16/unclear) vs. 37% (11/30); p=NR
Walach, et al., 2008^97^ N=409 Good | CDC (Fukuda, 1994) criteria | 6 months treatment Followup to 18 months | A. Distant healing B. Usual care | Function outcomes: SF-36 physical functioning: NS SF-36 physical functioning subscale: NS Covariance analysis effect for blinded vs. unblinded treatment, 95% CI : −1.54 (SE 0.70) −2.91 to −0.18
Weatherly-Jones, et al., 2004^98^ N=86 Fair | Oxford (Sharpe, 1991) criteria | 6 months | A. Homeopathy B. Placebo | Fatigue outcomes: MFI-20 general fatigue scores improved at 6 months, mean (SD): 2.70 (3.93) vs. 1.35 (2.66), p=0.04; proportion with clinically significant improvement (≥3 points on scale): NS Physical fatigue: NS Mental fatigue: NS FIS Physical dimension: NS FIS Social dimension: NS Function outcomes: Functional Limitations Profile scores: NS
Williams, et al., 2002^99^ N=30 Fair | Oxford (Sharpe, 1991) criteria | 12 months (12 weeks treatment, 12 week washout, then 12 week crossover and 12 week washout) | A. Melatonin B. Phototherapy C. Placebo | Fatigue outcomes: (IQR) VAS score: NS (IQR) SF-36 vitality subscale scores: NS Function outcomes: (IQR) SF-36 physical functioning subscale scores: NS

Abbreviations: ACL = Acetyl-L-carnitine; CDC= Centers for Disease Control and Prevention; CGI= Clinical Global Impression change score; CI= confidence interval; CIS= Checklist of Individual Strength; FIS= Fatigue Impact Scale; g= gram; IQR= interquartile range; MFI-20= Multidimensional Fatigue Inventory 20-Item; N= sample size; NR= not reported; NS= not significant; PCL= Propionyl-L-carnitine; SD= standard deviation; SE= standard error; SF-36= 36-item Short Form Survey; SIP-8= Sickness Impact Profile 8-Item; VAS= visual analog scale; vs.= versus.

The evidence on CAM therapies was insufficient to draw conclusions because they were tested in single trials only, and trials had small sample sizes and important methodological limitations. No trials of CAM therapies found statistically or clinically significant improvements compared with placebo, usual care, or an alternative CAM approach. Adherence was low in one trial of a low sugar/low yeast diet but otherwise adherence and harms were not well reported.

A good-quality trial (n=57) compared Acclydine^©^, a combination of amino acids and a food supplement derived from the plant Solanum dulcamara proposed to increase biologically active insulin-like growth factor (IGF-1), with an identical placebo.95 Patients were identified based on the CDC (Fukuda, 1994) criteria and followed over 14 weeks for measures of fatigue and function. No differences were detected for fatigue severity based on the CIS fatigue severity subscale questionnaire (1.1; 95% CI, −4.4 to 6.5) or self assessed daily fatigue level (−0.2; 95% CI, −1.2 to 0.9). There were no differences in function based on the SIP-8 (59.1; 95% CI, −201.7 to 319.8), and physical activity measured with an actometer motion-sensing device (4.1; 95% CI, −5.9 to 14.0).95 Of note, there was also no difference in IGF-1 blood levels between groups. Attrition was low and no harms were reported.

A fair-quality study (n=89) compared acetyl-L-carnitine (2 g/day) with propionyl-L-carnitine (2 g/day) and with a combination of both.96 Patients were eligible based on CDC (Fukuda, 1994) criteria. Outcomes compared CGI and MFI-20 comparing scores 8 weeks prior to intervention with those obtained after 24 weeks of treatment. Attrition was 20 percent attrition (18 of 90 enrolled) and adherence was not reported. Although some scores improved from baseline (CGI for acetyl-l-carnitine, 59%, propionyl-L-carnitine, 63%), between group differences were not reported. For the secondary outcomes of fatigue, propionyl-L-carnitine and the combination therapy showed a reduction on the 20-point general fatigue axis (from 18.4 SD 1.8 to 16.5 SD 3.1, and from 19.1 SD 1.4 to 17.3 SD 3.3, respectively), whereas acetyl-L-carnitine showed a reduction on the 20-point mental fatigue axis (from 16.3 SD 2.5 to 13.9 SD 3.5). No differences were found on the physical fatigue axis. Patients reported sleeplessness and feeling overstimulated although withdrawal due to harms were similar between groups. Although improvement was found on several measures compared to baseline measurements, the evidence leaves no indication whether one formulation was truly superior to another.

A poor-quality crossover trial randomized 22 patients to an extract of pollen (antioxidant) or placebo for 3 months followed by a 2-week washout and then to the pollen extract or placebo for an additional 3 months. Outcome measures included total well-being, fatigue, and fatigability on a non-standard 10-point Likert scale (0 =no problem and 10=serious symptoms).94 No differences were detected. Adherence was not reported and no serious harms were noted.

A fair-quality trial (n=86), randomized patients diagnosed with CFS based on the Oxford (Sharpe, 1991) criteria to homeopathy or placebo.98 Homeopathic prescriptions included different single or multiple remedies prescribed at monthly consultations over a 6-month period. Patients randomized to homeopathy had improved scores on the general fatigue subscale of the MFI-20 (mean change 2.70, SD 3.93 vs. 1.35, SD 2.66, p=0.04), but no differences on other dimensions or on the Fatigue Impact Scale or in the proportion of patients with significant clinical improvement (change from baseline of 15% on MFI-20 subscales). A secondary measure also improved, but its clinical significance is unclear (physical dimension subscale of the Functional Limitations Profile (FLP) with a mean change of 5.11 (SD 8.82) compared with 2.72 (SD 8.40) in the placebo arm). Attrition was similar between groups (overall 11 of 103, 11%) and neither adherence nor harms were reported. Although some improvement was noted in some measures, the lack of specificity in the treatment received and the inconsistencies in results leave uncertainty regarding any potential benefit.

A small (n=39) fair-quality trial compared a low sugar/low yeast diet with healthy eating in a group of primarily female patients (88%) diagnosed with ME/CFS using the CDC (Fukuda, 1994) criteria.93 The low sugar/low yeast diet involved omission of all sugar containing foods, refined carbohydrates, yeast containing foods, alcohol, and caffeine with a limited consumption of fruit and milk except a daily yogurt. Those randomized to the healthy eating approach were advised to consume a high fiber diet with five servings of fruit and vegetables per day, two servings of fish per week, and reduced fat and refined carbohydrates. Patients were followed for 24 weeks for outcomes of fatigue and quality of life. Results indicated no differences in either outcome based on the Chalder Fatigue Scale and the SF-36 but did note high loss to followup (25%, which were not included in analysis) and low adherence (24% in the low sugar/low yeast group vs. 67% in the healthy eating group).

A good-quality trial (n=409) randomized patients to immediate versus deferred distant healing (waiting) and used the CDC (Fukuda, 1994) or Oxford (Sharpe, 1991) criteria to determine inclusion.97 The median duration of illness ranged from 9.6 to 11.9 years. The intervention included healers from 21 European countries who had a mean healing experience of 9.7 years (SD 7.9 years). Healers were replaced if they did not comply with the study design (34 of 462, 7%). The Physical Health Component Summary score of the SF-36 was the secondary outcome of the study and indicated no differences between groups (1.11; 95% CI, −0.255 to 2.473). Although there was no interaction effect for treatment and blinding (p=0.32), patients who knew they were not being treated had lower scores at followup (mean difference between groups: −1.544; 95% CI, −2.913 to −0.176).97

A fair-quality crossover study compared melatonin and phototherapy with placebo.99 Thirty patients identified using the Oxford (Sharpe, 1991) criteria were given placebo initially for 12 weeks followed by melatonin (5 mg every evening) or phototherapy (2500 Lux for 1 hour in the morning). This was followed by a 12-week washout (phototherapy group) or placebo (melatonin group) and then a crossover to the reverse schedule.99 The study reported no differences on a 10-point VAS of fatigue, the Mental Fatigue Inventory, or the SF-36 physical functioning dimension.

In summary, there is insufficient evidence to determine the effectiveness or harms of CAM interventions because only small single studies with methodological limitations are currently available.

#### Counseling and Behavior Therapies

Fourteen trials (23 publications) comparing one counseling or behavioral therapy with usual care, wait list control, no treatment, relaxation techniques only, adaptive pacing, anaerobic therapy, GET, or an alternate form of counseling or behavioral therapy met inclusion criteria.100–121 Eleven trials (16 publications) included only counseling and behavior therapies as the active intervention compared with a control group100,102–104,107,109,110,112–120 and two trials (6 publications) included an exercise group as a comparison group, in addition to a control group.105,106,108,121–123 The results that pertain to the comparisons between the counseling or behavior therapy and “control” groups (defined as wait list, no treatment, usual care, support, relaxation, and adaptive pacing) on outcomes will be discussed in this section (Table 5 below; Table G4); results based on comparisons with exercise programs or GET will be discussed in the Exercise Program section below. One trial compared face-to-face cognitive behavioral therapy (CBT) with telephone CBT and did not include a control group.101 All trials were designed to target symptoms of ME/CFS, not treat the underlying cause. Five trials were rated good-quality,113,114,116,118,121 six fair-quality,100–102,108,109,112 and three poor-quality104,107,110 (Table H2). Most of the trials (64%) were of small sample size (n<100), predominately enrolled females (54 to 100%), with mean ages ranging from 31 to 58 years, and the duration of illness ranged from 6 months to 52 years. Half of the trials used the CDC (Fukuda, 1994) criteria to identify people with ME/CFS, while others used the Oxford (Sharpe, 1991) criteria, one developed by Schluederberg in 1992, and one study instead used a combination of a CFS questionnaire, psychiatric assessment, and medical assessment to rule out other conditions and diagnose ME/CFS.108

Table 5 Trials of counseling and behavioral therapies for ME/CFS

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Overall Effect Intervention A vs. Intervention B vs. Intervention C, etc.
Bazelmans, et al., 2005^100^ Nonrandomized trial N=65 Fair | CDC (Fukuda, 1994) | 6 months | A. Group CBT B. Wait list control | Function: Functional impairment improved in control group on SIP-8 at 6 months, mean change in scores from baseline: 29 vs. −293; p=0.004 Fatigue: CIS: NS Employment: Hours worked/week: NS Harms: Not reported
Burgess, et al., 2012^101^ N=43 Fair | CDC (Fukuda, 1994) and Oxford (Sharpe, 1991) criteria | 12 months | A. Face-to-face B. Telephone | Function: SF-36 physical functioning subscale: NS for between groups; p=0.043 for change from baseline for both groups Fatigue: Chalder Fatigue Scale scores: NS Employment: Work and social adjustment scale scores: NS for between groups; p=0.013 for change from baseline for both groups Other: Global improvement score of “much better or very much better” at 6 and 12 months were higher in the face-to-face group: 60% (15/25) vs. 40% (8/20), 12 months: 57% (13/23) vs. 55% (11/20)’ p=NR Harms: Not reported
Deale, et al., 1997^102^ N=60 Deale, et al., 2001^103^ N=53 Fair | Oxford (Sharpe, 1991) and United States (Schluederberg, 1992) criteria | Deale, 1997: 6 months Deale, 2001: 5 years | A. CBT B. Relaxation | Function: % With good outcome on SF-36 physical functioning subscale better in CBT group at 6 months: 63% (19/30) vs. 17% (5/30); difference of 46% (95% CI, 24 to 68), p<0.001 5 year followup: NS Functioning rating by assessor at 3 months as “better or much better” higher in CBT group: 80% (20/25) vs. 26% (6/23); p<0.001 Fatigue: Fatigue rating by assessor at 3 months as “better or much better” higher in the CBT group: 72% (18/25) vs. 17% (4/23); p<0.001 Non-cases of fatigue (score <4 on Chalder Fatigue Scale) at 6 months higher in the CBT group: 63% (17/27) vs. 15% (4/26); p=0.001 5 year followup: NS Employment: Work and social adjustment scale subscale scores better in CBT at 6 months, mean (SD): 3.3 (2.2) vs. 5.4 (1.8) p<0.001, between group differences over time Hours worked per week at 5 years was higher in CBT group, mean (SD): 35.57 (8.11) vs. 24.00 (4.97); p<0.04 % With full- or part-time employment at 5 year followup: NS Other: Global improvement rating “better or much better” higher in the CBT group at 6 months: 70% (19/27) vs. 31% (8/26); p<0.01 Global improvement rating “better or much better” higher in the CBT group at 5 years: 68% (17/25) vs. 36% (10/28); p=0.05 Outcomes at 5 year followup: Symptoms “steadily improved” not “consistently absent’ or “mild” higher in the CBT group: 68% (17/25) vs. 43% (12/28); p=0.05 Complete recovery higher in the CBT group: 24% (6/25) vs. 4% (1/28); p=0.04 No relapses higher in the CBT group: 36% (9/25) vs. 7% (2/28); p=0.02 Fewer number of relapses in CBT group, mean (SD): 2.58 (2.21) vs. 4.08 (1.55); p<0.01 No longer meeting U.K criteria for CFS: 52% (13/25) vs. 39% (11/28); p=NS Harms: Not reported
Goudsmit, et al., 2009^104^ N=44 Poor | Oxford (Sharpe, 1991) criteria | 6 months | A. Counseling B. Wait list | Function: Functional impairment scale scores: NS Fatigue: Profile of fatigue-related symptoms scale scores better in counseling group at 6 months, mean (SD): 2.68 (1.41) vs. 3.84 (1.40); p=0.04 Harms: Not reported
Jason, et al., 2007^108^ Jason, et al., 2009^106^ Hlavaty, et al., 2011^105^ N=114 Fair Same study as on Table 7 | CFS Questionnaire, psychiatric assessment for DSM-IV diagnosis, and medical assessment | 12 months | A. CBT B. COG C. ACT D. Relaxation | Function: Functional scores better in CBT, COG, and relaxation group than ACT on SF-36 physical functioning subscale scores at 12 months, mean (SD): 58.64 (30.44) vs. 61.09 (23.74) vs. 39.72 (27.63) vs. 61.20 (27.70) p<0.01, for CBT and COG over time vs. ACT over time Comparison by energy envelope for those who stayed within envelope vs. outside envelope at 12 months: 65 vs. 43, change at 12 months from baseline: 17 vs. 0; p=0.03 Comparison by homework compliance level, change in score at 12 months from baseline: 6.99 (19.30) vs. 7.55 (18.85) vs. 17.50 (18.09); p=NR % Achieving clinically significant improvement: NS Fatigue: Fatigue scores better in CBT group for FSS scores at 12 months, mean (SD): 5.37 (1.19) vs. 5.87 (1.01) vs. 5.77 (1.43) vs. 5.62 (1.06); p=NR Comparison by energy envelope for those who stayed within envelope vs. outside envelope at 12 months was 5.3 vs. 6.3 Change at 12 months from baseline: −0.9 vs. 0.1; p<0.01 The comparison by homework compliance level, change in score at 12 months from baseline: −0.17 (0.73) vs. −0.51 (1.00) vs. −0.54 (1.09); p=NR Quality of life: Quality of life slightly better in COG group based on QLS scores at 12 months mean (SD): 69.10 (18.99) vs. 72.52 (10.84) vs. 63.00 (13.86) vs. 72.00 (19.70); p=NR Employment: % Employed at 12 month followup: NS Harms: Not reported
Jason, et al., 2010^107^ N=30 Poor | CDC (Fukuda, 1994) criteria | 4 months | A. Buddy counseling B. Control, no treatment for 4 months | Function: SF-36 physical functioning subscale: NS Fatigue: FSS scores better in buddy counseling group at 4 months, mean (SD): 52.9 (10.5) vs. 59.4 (3.7); p=0.04 SF-36 vitality subscale scores better in buddy counseling group at 4 months, mean (SD): 29.3 (13.9) vs. 24.7 (9.7); p<0.05 Harms: Not reported
Knoop, et al., 2008^109^ Tummers, et al., 2010^115^ N=169 Fair | CDC (Fukuda, 1994) criteria | 6–12 months depending on length of treatment | A. Self-instruction B. Wait list control Tummers, 2010 A. Stepped care B. Usual care | Function (Knoop): SF-36 physical functioning subscale better in self-instruction group at second assessment, mean (SD): 65.9 (23.2) vs. 60.2 (23.7); p=0.011 Functional impairment SIP-8 scores worse in self-instruction group at second assessment, mean (SD): 1,515 (545) vs. 1,319 (619); p<0.001 Tummers, 2010 additional stepped care vs. usual care analysis Fatigue (Knoop): CIS fatigue severity scores better in self-instruction group at second assessment, mean (SD): 38.9 (12.1) vs. 46.4 (8.7); p<0.001 % With reduction in CIS fatigue severity scores higher in self-instruction group: 27% (23/84; 95% CI 18 to 37) vs. 7% (6/85; 95% CI 2 to 13); OR 4.9 (95% CI, 1.9 to 12.9); p<0.001 Function: SF-36 physical functioning subscale: NS Fatigue: CIS fatigue severity scores: NR % With reduction in CIS fatigue severity scores: NR Other: Number of CBT sessions for stepped care vs. usual: 10.9 (4.4) vs. 14.5 (5.3); p<0.01 Median minutes in sessions (range): 420 (120–1,440) vs. 720 (120–2,040); p=0.01 Harms: Not reported
Lopez, et al., 2011^110^ N=58 Poor | CDC (Fukuda, 1994) criteria | 3 months (12 weeks) | A. Group CBT B. Control, 1 session of psychoeducation summarizing strategies | Fatigue: POMS-Fatigue subscale: NS Quality of life: Category scores with lower scores indicating better health after treatment better in group CBT, mean (SD): 2.81 (1.15) vs. 3.26 (0.87); p=0.02 Raw score after treatment: 1.17 (1.83) vs. 0.82 (1.37); p=0.05 T score after treatment: 39.28 (14.17) vs. 36.42 (10.56); p=0.05 Harms: Not reported
O’Dowd, et al., 2006^112^ N=153 Fair | CDC (Fukuda, 1994) criteria | 12 months | A. Group CBT B. Group support C. Usual care | Function: Normal walking speed higher in CBT group on mean incremental shuttle walking test; at 6 and/or 12 months: 11.58 (0.71) vs. 9.82 (0.53) vs. 8.76 (0.47); p=0.006 Difference between groups from baseline to 12 months for CBT vs. support: 1.77 (95% CI, 0.025 to 3.51); p=0.0055 Difference between groups from baseline to 12 months for CBT vs. usual care: 2.83 (95% CI, 1.12 to 5.53); p=0.0055 SF-36 physical functioning subscale: NS Fatigue: Fatigue difference between groups from baseline for CBT vs. support at 12 months: −3.16 (95% CI, −5.59 to −0.74); p=0.011 Fatigue difference between groups from baseline for CBT vs. usual care at 12 months: −2.61 (95% CI, −4.92 to −0.30); p=0.027 Quality of life: Health related quality of life utility scores: NS Harms: Not reported
Sharpe, et al., 1996^113^ N= 60 Good | Oxford (Sharpe 1991) criteria | 12 months | A. CBT B. Usual care | Function: Functional scores of ≥80 on KPS better in CBT group at 12 months: 73% (22/30) vs. 27% (8/30); difference of 47% (95% CI, 24 to 69) Improvement of ≥10 points on KPS better in CBT group at 12 months: 73% (22/30) vs. 23% (7/30); difference of 50% (95% CI 28 to 72%) Harms: Not reported
Taylor, 2004^114^ N=47 Good | CDC (Fukuda, 1994) criteria | 12 months | A. Counseling B. Wait list | Quality of life: QLI scores better in counseling group at 12 months, mean (SD): 15.7 (3.7) vs. 14.6 (4.1); mean change from baseline: 2.6 vs. 0.6; p<0.05 Health and function subscale at 12 months: 14.1 (1.7) vs. 13.6 (1.8) Social and economic subscale at 12 months: 15.6 (0.8) vs. 15.5 (0.9) Psychological and spiritual subscale at 12 months: 15.5 (1.1) vs. 15.1 (1.2) Family subscale at 12 months: 15.6 (0.8) vs. 15.5 (0.9); mean change from baseline: 0.2 vs. −0.2; p<0.05 Harms: None withdrew due to harms, otherwise NR
Tummers, et al., 2012^116^ N=111 Good | CDC (Fukuda, 1994) criteria | 6 months | A. Self-instruction B. Wait list | Function: SF-36 physical functioning subscale (main analysis): NS Of those within the disabled range at baseline (SF-36 physical functioning subscale score ≤70, n=99), those in the self-instruction group improved more at the second assessment, mean change from baseline: 18.5 vs. 9.6, difference: 9.05 (95% CI, 0.2 to 17.9); p<0.05 Fatigue: Fatigue severity scores better in self-instruction group on CIS fatigue scale at second assessment, mean (SD): 39.6 (14.1) vs. 48.3 (8.1); p<0.01 % With reduction in CIS fatigue severity scores: 33% (18/55) vs. 9% (5/56); OR 5.0 (95% CI, 1.69 to 14.57) Of those within the disabled range at baseline (SF-36 physical functioning subscale score ≤70, n=99), those in the self-instruction group improved more at the second assessment, mean change from baseline: −12.4 vs. −2.4; difference: −9.9 (95% CI, −5.4 to −14.3); p<0.01 Harms: Not reported
Tummers, et al., 2013^117^ “See Knoop, 2008 and Tummers, 2012” (Fair) Secondary analysis of Knoop, et al., 2008 & Tummers, et al., 2012 combined | CDC (Fukuda, 1994) criteria | 6–12 months (based on the RCTs) | A. Self-instruction B. Wait list | Fatigue: Interaction tests for potential moderators from linear regression models (95% CI): Age (years): 0.15 (0.01 to 0.045); p<0.05 Depression: 0.15 (0.04 to 1.95); p=0.04 Avoidance of activity: 0.17 (0.03 to 1.78); p=0.04 Perpetuating factors: self-efficacy: NS, somatic attribution: NS, focus on bodily symptoms: NS Interaction tests for potential moderators from logistic regression models (95% CI): Avoidance of activity: 1.34 (1.03 to 1.74); p=0.03 Depression: 1.40 (1.08 to 1.82); p=0.01 Age (years): NS Perpetuating factors: self-efficacy: NS, somatic attribution: NS, focus on bodily symptoms: NS Harms: Not reported
Wearden, et al., 2010^118^ FINE Trial Wearden, et al., 2012^119^ Wearden, et al., 2013^120^ N=257 Good | Oxford (Sharpe, 1991) criteria | 4.5 months (18 weeks) treatment; 17.5 months (70 weeks) total followup | A. Pragmatic rehab B. Supportive listening C Usual care | Function: Functional scores better in usual group on SF-36 physical functioning subscale at 20 weeks, mean (SD): 39.94 (25.21) vs. 33.28 (22.94) vs. 40.27 (26.45); treatment effect estimate −7.54; 95% CI, −2.96 to −0.11; p=0.035 for supportive listening vs. usual care At 70 weeks: NS Fatigue: Chalder Fatigue Scale scores at 70 weeks: NS Significant regression coefficients for interaction between putative moderators and treatment: HADS baseline depression score: −0.67 (95%, CI −1.25 to −0.10); p=0.022 HADS baseline total score: −0.30 (95% CI, −0.58 to −0.02); p=0.039 EQ-5D self-care scale, those with severe problems: −28.72 (95% CI, −32.14 to −25.31); p<0.001 Significant regression coefficients to predict change in Chalder Fatigue Scale scores: Age: −0.10 (95% CI, −0.19 to −0.003); p=0.044 Duration of illness: −0.01 (95% CI, −0.02 to −0.003); p=0.008 EQ-5D mobility scale; those with severe problems: −2.95 (95% CI, −5.51 to −0.40); p=0.024 Harms: Overall: 4 (herpes simplex infection, attempted suicide, bleeding peptic ulcer, and recurrence of cancer; all deemed unrelated to interventions)
White, et al., 2011^121^ PACE Trial N=480 Good Same study as on Table 6 and 7 | Oxford (Sharpe, 1991) criteria | 13 months (52 weeks) | A. CBT B. APT D Usual care | Function: Functional scores better in CBT group on SF-36 physical functioning subscale at 52 weeks, mean (SD): 58.2 (24.1) vs. 45.9 (24.9) vs. 50.8 (24.7) Mean difference CBT vs. APT at 52 weeks (95% CI): 10.5 (5.4 to 15.6) p=0.0002 Mean difference CBT vs. usual care at 52 weeks (95% CI) : 7.1 (2.0 to 12.1) p=0.0068 % Improved from baseline (by ≥8 points) was higher in CBT group: 71% (105/148) vs. 49% (75/153) vs. 58% (88/152) 6MWT: NS Fatigue: Fatigue scores better in CBT group on Chalder Fatigue Scale at 52 weeks, mean (SD): 20.3 (8.0) vs. 23.1 (7.3) vs. 23.8 (6.6) Mean difference CBT vs. APT at 52 weeks (95% CI): −2.7 (−4.4 to −1.1) p=0.0027 Mean difference CBT vs. usual care at 52 weeks (95% CI): −3.4 (−5.0 to −1.8) p=0.0001 % Improved from baseline (by ≥2 points) was higher in the CBT group: 76% (113/148) vs. 65% (99/153) vs. 65% (98/152) Employment: Work and social adjustment scale scores better in CBT group at 52 weeks, mean (SD): 21.0 (9.6) vs. 24.5 (8.8) vs. 23.9 (9.2); p=0.0001 for CBT vs. control and CBT vs. APT Other: More with positive change in CBT group on self-rated CGI at 52 weeks: 41% (61/147) vs. 31% (47/153) vs.25% (38/152) Minimum change: 52% (77/147) vs63% (96/153) vs.66% (100/152) Negative change: 6% (9/147) vs. 7% (10/153) vs. 9% (14/152) The positive change vs. negative change, OR (95% CI) CBT vs. APT: 1.7 (1.0 to 2.7) p=0.034 CBT vs. usual care: 2.2 (1.2 to 3.9) p=0.011 Harms: Number of nonserious adverse events: 848 vs. 949 vs. 977, p=0.0081 for CBT vs. APT and p=0.0016 for CBT vs. control % with physical function worse: 9 (15/161) vs. 25 (39/159) vs. 18 (28/160); p=0.0007 % With ≥1 nonserious adverse event: NS % With serious adverse events: NS % With serious adverse reactions: NS

Abbreviations: 6MWT=6 minute walk test; ACT= anaerobic activity therapy; APT= adaptive pacing therapy; CBT= cognitive behavioral therapy; CDC= Centers for Disease Control and Prevention; CFS= chronic fatigue syndrome; CI= confidence interval; CIS= Checklist of Individual Strength; COG= cognitive therapy; DSM-IV= Diagnostic and Statistical Manual fourth edition; FSS= fatigue severity scale; HADS= Hospital Anxiety and Depression Scale; KPS= Karnofsky Performance Scale; N= sample size; NR= not reported; NS= not significant; OR= odds ratio; POMS= Profile of Mood States; QLI= Quality of Life Index; QLS= Quality of life scale; RCT= randomized controlled trial; SD= standard deviation; SF-36= 36-item Short Form Survey; SIP-8= Sickness Impact Profile 8-Items; U.K.= United Kingdom; vs. = versus.

Five used cognitive and CFS specific techniques,100,108,112,113,121 one used CBT techniques focused on activity,102 one used traditional CBT techniques aimed at a CFS population delivered either over the phone or face-to-face,101 and one used relaxation, didactic discussion, and cognitive techniques for CFS.110 Three of the interventions were conducted in group formats100,110,112 instead of individual. Three good-quality,114,116,118 one fair-quality,109 and two poor-quality104,107 trials evaluated other counseling techniques, which included guided self-instruction programs, group illness management instruction, pragmatic rehabilitation, peer-to-peer counseling, and symptom consultation.

The largest trial was the PACE trial, a 12 month good-quality 4-arm trial that included a comparison of CBT (n=155) with adaptive pacing (n=159), and usual care (n=157). This trial measured outcomes of fatigue (Chalder Fatigue Scale), function (SF-36 physical function subscale), clinical global impression of change, and work impairment (work and social adjustment scale).121 The GET arm is discussed in the Exercise Therapies and Head-to-Head/Comparison Trials Sections. Patients were selected from multiple specialty care centers in the United Kingdom and were eligible based on the Oxford (Sharpe, 1991) criteria for CFS as well as a Chalder fatigue score of 6 or greater (of possible 11) and SF-36 score of 60 or less (of possible 100), which was subsequently changed to 65 or less to increase enrollment. CBT was based on the fear avoidance theory of ME/CFS that regards symptoms as being “reversible and that cognitive responses (fear of engaging in activity) and behavioral responses (avoidance of activity) are linked and interact with physiological processes to perpetuate fatigue.”121 CBT consisted of up to 14 individual sessions over 23 weeks, with a booster session at 36 weeks. The aim was to “change the behavioral and cognitive factors assumed to be responsible for perpetuation of the participant’s symptoms and disability.”121 Strategies guided participants to address unhelpful cognitions, including fears about symptoms or activity, by testing them in behavioral experiments consisting of gradual increases in both physical and mental activity. Adaptive pacing consisted of a maximum of 15 sessions of therapy aimed at achieving optimum adaptation to the illness through activity pacing and advice to avoid activities that demand more than 70 percent of participant’s perceived energy; therapy was delivered by occupational therapists. Usual care was provided by physicians specializing in ME/CFS. In other studies, CBT and adaptive pacing had similar aims and strategies. Pragmatic rehabilitation was also based on a physiological dysregulation theory of ME/CFS with patients and therapists collaboratively setting goals for activity, sleep, and cognitive function.118 Counseling and supportive listening were empathic and nondirective in nature.

Adherence was not reported in eight of the trials,100,102,104,107,109,110,116,121 one trial only reported that the adherence was “good,”114 while another trial stated that all completed CBT.113 One trial reported that 28 percent of participants did not receive their intended treatment.101 One trial reported that the participants completed an average of 10 out of 13 counseling sessions, but no other information,108 and two trials reported contamination, not specifically adherence (6% in the CBT group received support, while 8% in the support group received CBT112 and 3% in the counseling group received support, while 1% in the support group received pragmatic rehabilitation and 10% in the support group did not receive any treatment).118 Attrition was reported in most trials and was generally low (<20%) and similar between groups. Three trials reported high or differential attrition; two trials were in group settings, but reported opposite information, with higher attrition in group CBT compared with control (14% vs. 20%)110 in one trial and higher attrition in the usual care group compared with group CBT (14% vs. 25%) in the other trial.112 The third trial reported higher attrition in the telephone CBT group compared with the face-to-face CBT group, but both were high (56% vs. 34%).101 One trial conducted a stepped care approach, providing participants with a self-instruction program to follow for 16 weeks or delayed care followed by CBT; this study found that after 16 weeks, 57 percent of those in the self-instruction group and 22 percent in the delayed group did not want to continue on to CBT, and therefore dropped out of the study.115 Major limitations of these trials included enrolling fewer than 20 subjects in an arm,107 high loss to followup,101 unclear if use of intention-to-treat analysis,104,107,108,110 unclear randomization or allocation process,100,104,107,108,110,114 more men allocated to the intervention group,112 and lack of or unclear information about blinding of the outcome assessor.100,101,104,108,109,113,114,116 Due to the nature of the interventions, most trials could not blind patients or care providers. Trials were either funded by government or organizational grants (fully or in part)100,104,107,108,110,112–114,116,118,121 or the funding source was not reported.101,109

There is low strength evidence, based on 14 trials, that CBT, either group or individual; self-instruction booklets; pragmatic rehabilitation; peer-to-peer counseling; and symptom consultation provide improvement in fatigue, function, quality of life, and employment in adult patients with ME/CFS. When comparing any type of counseling or behavioral therapy to no treatment, support, relaxation, or adaptive pacing there is low strength of evidence that counseling decreases fatigue (7 of 11 trials showed positive effect) and improves functioning measures (4 of 11 trials showed positive effect; 2 of 11 showed mixed results on measures), quality of life (2 of 4 trials showed positive effect), and global improvement (2 of 2 trials showed positive effect). Harms of counseling and behavioral therapies were poorly reported, but there is low strength of evidence that CBT is not associated with harms based on one moderate-sized trial.

##### Function Outcomes

Eleven trials (n=1,720) of counseling techniques compared with no treatment, support, relaxation, or adaptive pacing, reported overall functioning measured by the SF-36 physical functioning subscale, KPS, SIP-8, and the functional impairment scale.100,102,104,107–109,112,113,115,118,121 Results were mainly positive, but mixed. In four trials102,108,113,121 counseling improved overall functioning compared with controls on various measures, while two trials reported mixed results using different measures in the same study,109,112 one trial reported improvement in the control group compared with counseling,100 and the other four trials reported no differences between groups.104,107,115,118

Eight trials used the SF-36 physical functioning subscale to measure overall functioning102,107–109,112,115,118,121 and results were mixed. Four trials102,108,109,121 reported significantly more improvement in the CBT group compared with controls (71% vs. 49% improved by ≥8 points from baseline at 1 year, p=0.0068^121^ and 63% vs. 17% with a score >83 at 6 months followup, p<0.001^102^) or better scores (mean scores of 58.64 vs. 39.72 at 1 year, p<0.01^108^ and mean scores of 65.9 vs. 60.2 at about 6–12 months, p=0.011^109^). However, by 5 years in one trial the results were no longer significantly different,103 and in another trial on the SIP-8 the outcome was reversed with worse functioning reported in the self-instruction group compared with the wait list control (mean scores of 1,515 vs. 1,319, p<0.001).109 The other four trials reported no differences between the counseling group and controls.107,112,115,118 However, one trial also measured functioning using a walking speed test and found improved walking speed in the CBT group compared with controls (difference from baseline to 12 months for CBT vs. support: 1.77; 95% CI, 0.025 to 3.51; p=0.0055 and difference from baseline to 12 months for CBT vs. no intervention: 2.83; 95% CI, 1.12 to 5.53; p=0.0055).112 Another trial conducted a post hoc analysis on those with baseline functional disability (defined as SF-36 physical functioning baseline score ≤70) and reported a significant improvement in the self-instruction group compared with the wait list control (mean change from baseline CBT vs. control: 9.05; 95% CI, 0.2 to 17.9; p<0.05).115 When trials using the SF-36 physical functioning subscale were pooled there was a significant effect for the intervention group to have better scores compared with controls at followup; weighted mean difference of 7.73 (95% CI, 3.58 to 11.87, Figure 3). Even when one outlier that showed a more significant difference than the other trials102,103 was removed the difference was still significant with a weighted mean difference of 7.18 (95% CI, 4.53 to 9.83). However, when the analysis was limited to the four trials that used formal CFS specific CBT techniques, though the result was similar, the difference was no longer significant owing to the wide CI (weighted mean difference of 9.12, 95% CI, −3.10 to 21.35, p=0.14, I^2^=69%).102,108,112,121

Figure 3 Meta-analysis of mean changes in SF-36 physical function subscale scores for CBT compared with controls

* Using support as the comparison

† Using usual care as the comparison

‡ Using adaptive pacing as the comparison

Abbreviations: CBT= cognitive behavioral therapy CI= confidence interval; N= sample size; SF-36= Short Form 36-item survey.

Figure 3 is a forest plot of 8 studies reporting the weighted mean differences in changes on the SF-36 physical functioning subscale for CBT versus controls. Data for Figure 3 are presented in Appendix G4, Table 3. This figure is described further in the section on Cognitive and Behavioral Therapies as follows: “When trials using the SF-36 physical functioning subscale were pooled there was a significant effect for the intervention group to have better scores compared with controls at followup; weighted mean difference of 7.73 (95% CI, 3.58 to 11.87). Even when one outlier that showed a more significant difference than the other trials 78,79 was removed the difference was still significant with a weighted mean difference of 7.18 (95% CI, 4.53 to 9.83).”

One trial used the KPS to measure overall functioning113 and reported significantly more improvement in the CBT group compared with controls (73% vs. 23% improved by ≥10 point at 12 months; difference of 50% CBT vs. no intervention; 95% CI, 28 to 72%).

One trial only used the SIP-8 to measure overall functioning100 and reported worse functional impairment in the CBT group compared with the wait list control (mean change from baseline at 6 months: 29 vs. −293; p=0.004). Along with the other outcomes reported above, the SIP-8 showed mixed results. One trial only used the functional impairment scale to measure overall functioning and found no differences between counseling and the wait list control at 6 months followup.104

The PACE trial performed a sensitivity analysis for those patients who fulfilled the CDC (Reeves, 2003) criteria for CFS (n=321) and for those patients who fulfilled the London (Dowsett, 1994) criteria for ME (n=245) at baseline and found similar results for the outcomes of function; however, primary data were not provided.121–123

##### Fatigue Outcomes

Eleven trials (n=1,691) of counseling compared with no treatment, support, relaxation, or adaptive pacing, reported decreased fatigue measured by the Chalder Fatigue Scale, FSS, CIS, POMS-fatigue, Profile of fatigue-related symptoms scale, and the SF-36 vitality subscale.100,102,104,107–110,112,115,118,121 Results were primarily positive, but mixed. In seven trials counseling significantly decreased fatigue compared with controls on various measures,102,104,107,109,112,115,116,121 while the other four trials showed no differences between groups.100,108,110,118

Four trials used the Chalder Fatigue Scale to measure fatigue102,112,118,121 and results were primarily positive. Three trials reported significantly more decreases in fatigue in the counseling group compared with the controls (63% vs. 15% were non-cases of fatigue with a score <4 at 6 months; p=0.001^102^) or better scores (difference in scores from baseline at 1 year for CBT vs. support: −3.16; 95% CI, −5.59 to −0.74; p=0.011 and CBT vs. no intervention: −2.61; 95% CI, −4.92 to −0.30; p=0.027^112^ and at 52 weeks for CBT vs. no intervention: −3.4; 95% CI, −5.0 to −1.8; p=0.0001^121^). However, by 5 years in one trial the results were no longer significantly different.103 The other trial that used the Chalder Fatigue Scale reported statistically significantly better fatigues scores in the pragmatic rehabilitation group than the usual care group (treatment effect estimate of −1.18; 95% CI, −2.18 to −0.18; p=0.021), but by 70 weeks there were no differences.118 Due to the variability in how the Chalder Fatigue Scale was used across studies, these results could not be pooled.

Three trials used the CIS to measure fatigue100,109,115 and results were primarily positive. Two trials reported significantly less fatigue in the counseling groups compared with the controls (27% vs. 7% improved at about 6 to 12 months; OR 4.9; 95% CI, 1.9 to 12.9; p<0.001,^109^ and 33% vs. 9% at 6 months; OR 5.0; 95% CI, 1.69 to 14.57;^116^ both used a reliable change score of >1.64 and final score of ≤36 to indicated improved). Only one non randomized trial found no differences between groups at 6 months.100

Two trials used the FSS to measure fatigue107,108 and both found significantly lower fatigue scores in the counseling groups compared with the controls (mean scores of 52.9 vs. 59.4 at 4 months; p=0.04^107^ and mean scores of 5.37 vs. 5.62 at 1 year, but p value not reported108). One trial conducted post hoc analyses and compared fatigue and functioning outcomes based on homework compliance.105 Homework included assignments such as of readings, sleep diaries, and activity diaries, and at home practices such as activity goals, relaxation exercises, and use of coping skills. They identified three groups based on the amount of homework completed; minimum compliance completed 0 to 25 percent, moderate compliance completed 25.1 to 75 percent, and maximum compliance completed 75.1 to 100 percent of their assigned homework. When they assigned individuals to groups they noted that the highest percentage in the maximum group (56%) were in the cognitive therapy group, the highest percentage in the moderate group (34%) were in the CBT group, and the highest percentage in the minimum group (38%) were in the anaerobic and relaxation groups. At 12 months, though there was a trend toward decreased fatigue and better improvement in functioning scores for the maximum compliance group compared with the other groups, this trend did not reach significance.

One trial used only the Profile of fatigue-related symptoms scale to measure fatigue104 and reported better scores in the counseling group compared with the wait list control (mean scores of 2.68 vs. 3.84 at 6 months; p=00.04), while one trial reported no differences in fatigue scores using the POMS.110

The PACE trial performed a sensitivity analysis for those patients who fulfilled the CDC (Reeves, 2003) criteria for CFS (n=321) and for those patients who fulfilled the London (Dowsett, 1994) criteria for ME (n=245) at baseline and found similar results for the outcome of decreased fatigue, but primary data were not provided.121–123

##### Quality of Life Outcomes

Four trials (n=372) of counseling compared with no treatment, support, or relaxation, reported quality of life measured by the QOLI, QLI, QLS, EuroQol, and the health utilities index.108,110,112,114 Results were mixed, but primarily positive. Two trials reported better scores in the counseling group compared with controls (mean QOLI scores at 12 weeks: 2.81 vs. 3.26; p=0.02^110^ and mean change in QLI scores from baseline at 12 months: 2.6 vs. 0.6; p<0.05^114^), one trial108 reported slightly better scores on the QLI in the cognitive group compared with CBT and controls at 1 year, but the p value was not reported (69.10 for CBT vs. 72.52 for cognitive vs. 63.00 for anaerobic activity vs. 72.00 for relaxation), and the fourth study reported no differences between groups.112

##### Employment Outcomes

Four trials (n=869) of counseling compared with no treatment, support, relaxation, or adaptive pacing reported employment outcomes including proportion working full- or part-time, hours worked per week, and level of work impairment measured by the Work and Social Adjustment Scale.100,102,103,108,121 Results were primarily positive. Both trials measuring work impairment with the Work and Social Adjustment Scale reported significantly better scores for the CBT group compared with controls (mean scores of 3.3 vs. 5.4 at 6 months; p<0.001 on scale scored with range 0 to 8;102 mean scores of 21.0 vs. 24.5 at 1 year; p=0.0001 on scale scored with range 0 to 45^121^). Two trials reported the number of hours per week individuals were working. One trial reported significantly more hours worked per week, of those working, for the CBT group compared with relaxation (mean hours of 35.57 vs. 24.00 at 5 years; p<0.04)103 and the other trial reported no differences between groups.100 Two trials reported no differences in the proportion of individuals working full- or part-time at 1 year108 or 5 years.103

##### Global Impression of Improvement Outcomes

Two trials (n=690) of counseling compared with no treatment, relaxation, or adaptive pacing reported global improvement using the CGI, spontaneous reporting of fully recovered or feeling much better, relapses, full recovery, and no longer meeting ME/CFS criteria.102,103,121 Significantly more individuals in the CBT group reported improvement compared with controls in both trials (70% vs. 31%; p<0.01^102^ and 41% vs. 31%; p=0.013^121^). One trial103 also followed up 5 years after counseling and continued to report more improvement in the CBT group compared with relaxation (68% vs. 43% with symptoms “steadily improved” not “consistently absent’ or “mild”; p=0.05; 24% vs. 4% with complete recovery; p=0.04; 36% vs. 7% with no relapses; p=0.02; and mean number of relapses of 2.58 vs. 4.08; p<0.01); however, there was no difference in the number of individuals currently meeting the Oxford (Sharpe, 1991) criteria for ME/CFS (52% vs. 39%; p=0.42).

##### Recovery Outcomes

The PACE trial considered the outcome of recovery (trial recovery was defined as: within the normal range in fatigue [Chalder Fatigue Scale score <18] and physical function scales [SF-36 physical function subscale score ≥60], no longer meeting Oxford [Sharpe, 1991] criteria, and reporting much or very much improvement on the CGI scale; clinical recovery was defined as: meeting all criteria for trial recovery plus no longer meeting the London [Sharpe, 1991] or the CDC [Reeves, 2003] criteria).121 Although trial recovery remained low for all treatment arms (<25%), they found CBT to be superior to adaptive pacing therapy (OR 3.36; 95% CI, 1.64 to 6.88) and usual care (OR 3.69; 95% CI, 1.77 to 7.69), with similar results for clinical recovery. Although the PACE trial has performed measures to minimize risk of bias and is one of the best available in the ME/CFS literature given its size and methodology, there are limitations. Although blinding patients and providers to the intervention was not feasible, and statisticians were blinded, the study may be open to risk of observer bias by not blinding researchers assessing outcomes. They did, however use self-reported outcome measures to reduce the risk of observer bias, which are valid tools for measuring the outcomes of interest. The study may also be at risk of attention bias given the total number of visits by participants were greater in the CBT (17) and adaptive pacing (16) groups compared with the usual care group (5). The nature of the approach to CBT, using providers and training manuals that teach patients that the treatment is effective, can cause an expectation bias in the direction of improvement. Additionally, there are reservations about the interpretation of the recovery results. Given that a score of 65 or less on the SF-36 physical functioning scale was defined as disability for entry into the trial, using a score of 60 or greater on the same scale to define recovery is contradictory. The authors reportedly derived their threshold for recovery based on the mean score for a normal adult minus two SDs (84 to 16). Furthermore, they defined deterioration as greater than a 20 point reduction in the SF-36, yet they defined improvement as an increase of 8 point or more. These threshold values likely favor results in the direction of improvement. For fatigue outcomes they considered recovery as a Chalder Fatigue Scale score less than 18 yet other studies have considered a score of less than 4 to indicate a return to normal.118 Finally, although statistically significant changes were noted, the meaningfulness of these change remains uncertain. For instance, the mean score of the SF-36 physical function score remained at or above 60 (used in the definition of trial recovery) for all groups, while the 6-minute walk test was much less than for normal older adults (379 meters vs. 631 meters).124

##### Face-to-Face Versus Telephone CBT

One fair-quality trial (n=80) compared face-to-face CBT with telephone CBT, without using a control group,101 followed them for 12 months, and measured fatigue using the Chalder Fatigue Scale, functioning using the SF-36 physical functioning subscale, work impairment using the Work and Social Adjustment scale, and overall improvement using a self-rated global improvement Likert style scale, similar to the CGI scale (ranging from very much worse to very much better). There were no significant differences between groups on any of the outcomes at any time point. Both groups showed significant improvement at 12 months after the end of treatment from baseline on the SF-36 physical functioning subscale and the Work and Social Adjustment scale, and the majority of participants rated themselves as much better or very much better on the self-rated global improvement scale (56%).

##### Harms Outcomes

Only three good-quality trials reported anything about harms after counseling or behavior therapies. The PACE trial specifically defined adverse events as “any clinical change, disease or disorder experienced by the participant during their participation in the trial, whether or not considered related to the use of treatment” and serious adverse events as “an event that resulted in one of the following outcomes: a) death, b) threat to life (i.e., an immediate, not hypothetical, risk of death at the time of the event), c) required hospitalization except for elective treatment of a pre-existing condition, d) increased severity and persistent disability, defined as: (i) severe, i.e. significant deterioration in the participant’s ability to carry out their important activities of daily living (e.g. employed person no longer able to work, caregiver no longer able to give care, ambulant participant becoming bed bound); and (ii) symptom and disability persistent, i.e. of at least 4 weeks continuous duration, e) any other important medical condition which, though not included in the above, might require medical or surgical intervention to prevent one of the outcomes listed, and f) any episode of deliberate self-harm.”122 All serious adverse events were further analyzed after breaking blinding to determine whether the event was related to the intervention, which were deemed serious adverse reactions. Nonserious adverse events were reported often, however the CBT group reported significantly less (848) than both the adaptive pacing group (949, p=0.0081) and usual care group (977, p=0.0016).121 Although serious adverse events were uncommon, there were more reported in the adaptive pacing group (16) than the CBT group (8) or the usual care group (7), and there were more serious adverse reactions in the CBT group (4) compared with the adaptive pacing (2) or the usual care group (2). No one withdrew from CBT due to worsening. There was a significant difference in deterioration of physical function across treatment arms (adaptive pacing 25% vs. usual care 18% vs. CBT 9%, p<0.001), but no differences in serious deterioration defined by a composite score of reduced function, worsening clinical global impression, withdrawal rates, and serious adverse reactions.121,122

One small trial (n=47) reported none withdrew due to harms114 and a moderate-sized trial (n=257) reported no differences between groups for reported harms or withdrawals due to harms,118 but no other information was provide about harms.

##### Summary of Counseling and Behavior Therapy Trials

In summary, there is moderate strength of evidence that counseling techniques was associated with global improvement (41 to 70% vs. 25 to 31%), and low strength of evidence that counseling techniques improved overall functioning (SF-36 physical function weighted mean difference 7.73; 95% CI, 3.58 to 11.87), fatigue (27 to 76% vs. 7 to 65%), and employment outcomes in ME/CFS patients. The effects may not be generalizable to a more disabled population as no study used a case definition for ME and only one study analyzed patients fulfilling the London ME (Dowsett, 1994) case definition and may have been underpowered to detect a difference.121 Whether these effects can be sustained is uncertain as benefit was no longer seen in one trial that evaluated patients 5 years later. In addition, trials used various measures to detect change making it difficult to compare results and few trials reported the clinical significance, if available, of the improvement in scores. Recovery has rarely been tested and measurements used to determine effectiveness may be overestimating the effect and not reflective of true recovery. Harms were rarely reported Only one large trial (n=630), the PACE trial, reported significantly less harms in the CBT group.

#### Exercise Therapies

One good-quality121 and five fair-quality randomized trials compared one form of exercise with another form of exercise, standard medical care, adaptive pacing, or placebo (Table 6 below; Tables G4 and H2).90,125–128 Studies were conducted in the United Kingdom,90,121,125,128 United States,108 New Zealand,127 and China126 and enrolled patients based on the CDC (Fukuda, 1994) criteria108,126–128 or the Oxford (Sharpe, 1991) criteria.90,121,125 The majority of patients were female (range 68 to 82%), mean ages of 37 to 48 years, with mean duration of illness ranging from 28 to 36 months when reported.90,121,125,127 All were intended to target symptoms of ME/CFS. Major limitations of studies include dissimilarity of groups,125,127 high loss to followup,128 lack of intention-to-treat analysis of outcomes,128 and unclear or inadequate blinding.90,121,125–127 One trial was funded by a ME/CFS network and all other trials were funded by research agencies or trusts. GET was superior to control groups in measures of fatigue, clinical impression of change, and function. These findings however cannot be generalized to all patients with ME/CFS as no study enrolled patients whereby PEM was a diagnostic requirement (ME case definitions) and only one study performed a subgroup analysis to determine if similar results were found in patients meeting the diagnosis of ME. Recovery was only evaluated in one study and the clinical significance/meaningfulness of the results is questionable as several of the thresholds used to gauge recovery were lower than a normal population. The harms of exercise may be underestimated as it has been inadequately evaluated and reported particularly in patients with specific symptom subsets (i.e., PEM, autonomic dysfunction). Qigong exercise may be beneficial based on one small trial and home orthostatic training was ineffective based on one small trial but the evidence is insufficient without replication.

Table 6 Trials of exercise therapies for ME/CFS

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Overall Effect Intervention A vs. Intervention B vs. Intervention C, etc.
Chan, et al., 2013^126^ Ho, et al., 2012^126^ RCT N= 52 Fair | CDC (Fukuda, 1994) criteria | 4 months | A. Qigong exercise B. Control group | Function: SF-12 mental functioning subscale mean (SD): 42.7 (7.2) vs. 35.7 (9.5); p=0.001 SF-12 physical functioning subscale: NS Fatigue: Chalder Fatigue Scale mean (SD): 26.6 (13.6) vs. 33.2 (6.3); p<0.001 Physical fatigue scores, Chalder Fatigue Scale mean (SD): 15.9 (8.0) vs. 20.8 (5.7); p<0.001 Mental fatigue scores on Chalder Fatigue Scale mean (SD): 10.6 (6.1) vs. 12.4 (4.9); p=0.05 Other: Telomerase activity at 4 months (arbitrary unit): 0.178 (0.201) vs. 0.104 (0.059); p=0.029 Harms: Not reported
Fulcher and White, 1997^125^ RCT N=59 Fair | Oxford (Sharpe, 1991) criteria | 3 months (12 weeks), 1 year followup | A. Exercise group B. Control group | Function: SF-36 physical functioning subscale mean (SD): 69 (18.5) vs. 55 (21.8); p=0.01 Fatigue: Chalder Fatigue Scale mean (SD): 20.5 (8.9) vs. 27.4 (7.4); p=0.004 Physical fatigue scores better mean (SD): 130 (28) vs. 154 (34); p=0.006 Other VAS fatigue scores: NS Employment: working full- or part-time at 1 year followup: 66% (31/47) vs. 39% (26/66); 95% CI, 9% to 44% Other: Self-rated CGI scores of “very much better” :: 31% (9/29) vs.7% (2/30), p=0.05 Median (IQR) peak O_2_ consumption: NS Median increase in peak O_2_ consumption: NS Median increase in isometric strength: NS Harms: Total withdrawals: NS
Moss-Morris, et al., 2005^127^ RCT N= 49 Fair | CDC (Fukuda, 1994) criteria | 3 months (12 weeks), 6 month followup | A. Exercise group B. Control group | Function: SF-36 physical functioning: NS Fatigue: Chalder Fatigue Scale mean (SD): 13.91 (10.88) vs. 24.41 (9.69); p=0.02 Physical fatigue scores on Chalder Fatigue Scale mean (SD): 7.91 (7.06) vs. 14.27 (5.75); p=0.02 Mental fatigue scores on Chalder Fatigue Scale mean (SD): 6.00 (4.06) vs. 10.14 (4.27); p=0.03 Other: Self-rated CGI scores of % “much or very much improved” at 6 months: 54 (12/22) vs. 23.8 (5/21); p=0.04 Harms: Total withdrawals: NS
Sutcliffe, et al., 2010^128^ RCT N= 36 Fair | CDC (Fukuda, 1994) criteria | 6 months | A. Orthostatic training B. Control group | Function: Mean systolic blood pressure: NS Mean heart rate (beats per minute): NS Fatigue: Mean FIS scores: NS Harms: Not reported
Wearden, et al., 1998^90^ N=68 Fair Same study as on Table 3 and 7 | Oxford (Sharpe, 1991) criteria | 6.5 months (26 weeks) | A. GET B. Placebo control^*^ | Function: Functional work capacity based on amount of O_2_ consumed in the final minute of exercise per kg of body weight improved in GET group at 26 weeks, mean change (95% CI) : 2.8 (0.8 to 4.8) vs. −0.1 (−1.7 to 1.6) Effect of exercise on functional work capacity, mean change 0–26 weeks: 1.9 (95% CI 0.15 to 3.69), p=0.03 Fatigue: Fatigue scores significantly improved in GET group on Chalder Fatigue Scale at 26 weeks, mean change from baseline (95% CI): −5.7 (−9.5 to −1.9) vs. −2.7 (−5.4 to 0.01) Non-cases of fatigue on Chalder Fatigue Scale (score <4) at 26 weeks: 18% (6/33) vs. 6% (2/34), p=0.025 for exercise interventions combined vs. control Harms: Total withdrawals: GET > UC (11/34, 32% vs. 5/34, 15%)
White, et al., 2011^121^ PACE Trial N=479 Good Same study as on Table 5 and 7 | Oxford (Sharpe, 1991) criteria | 13 months (52 weeks) | A. GET B. APT C. Usual care^†^ | Function: SF-36 physical function subscale mean (SD): 57.7 (26.5) vs. 45.9 (24.9) vs. 50.8 (24.7) Mean difference vs. APT (95% CI): 12.8 (7.7 to 17.9) p<0.001 Mean difference vs. usual care (95% CI) : 9.4 (4.4 to 14.4) p<0.001 % Improved from baseline (by ≥8 points): 70% (108/154) vs. 49% (75/153) vs. 58% (88/152) Fatigue: CFS, mean (SD): 20.6 (7.5) vs. 23.1 (7.3) vs. 23.8 (6.6) Mean difference vs. APT (95% CI): −2.5 (−4.2 to −0.9) p<0.01 Mean difference vs. usual care (95% CI): −3.2 (−4.8 to −1.7) p<0.001 % Improved from baseline (by ≥2 points): 80% (123/154) vs. 65% (99/153) vs. 65% (98/152) Employment: Work and social adjustment scale, mean (SD): 20.5 (9.4) vs. 24.5 (8.8) vs. 23.9 (9.2); p<0.001 for GET Other: CGI positive change: 41% (62/152) vs. 31% (47/153) vs. 25% (38/152) CGI negative change: 7% (10/152) vs. 7% (10/153) vs. 9% (14/152) Positive change vs. Negative change, OR (95% CI) GET vs. APT: 1.5 (1.0 to 2.3) p=0.028 GET vs. usual care: 2.0 (1.2 to 3.5) p=0.013 Trial Recovery: GET vs. APT (OR 3.38, 95% CI, 1.65 to 6.93) GET vs. usual care (OR 3.71, 95% CI, 1.78 to 7.74 Harms: Serious adverse events: GET greater than usual care: 11 % (17/160) vs.4% (7/160), p=0.04 No difference: nonserious adverse events (992 vs. 949 vs. 977), serious adverse reactions (1%), serious deterioration (10/160, 6% vs. 13/159, 8% vs. 15/160, 9%); and total withdrawals (10/160, 6% vs. 11/159, 7% vs.14/160, 9%)

* Comparisons between Fluoxetine and placebo are presented in Table 2 and comparisons with GET + fluoxetine are presented in Table 6.

† Comparisons for CBT with APT and usual care are presented in Table 3 and comparisons for CBT with GET are presented in Table 6.

Abbreviations: APT= adaptive pacing therapy; CDC= Centers for Disease control and Prevention; CFS= chronic fatigue syndrome; CGI= Clinical Global Impression Change Score; CI= confidence interval; FIS= Fatigue Impact Scale; GET= graded exercise therapy; IQR= interquartile range; kg= kilogram; N= sample size; NR= not reported; NS= not significant; O_2_= oxygen; OR= odds ratio; RCT= randomized controlled trial; SD= standard deviation; SF-36= 36-item Short Form Survey; SF-12= Short Form 12-item Survey; UC=usual care; VAS= visual analog scale; vs.= versus.

##### Graded Exercise Therapy

The effectiveness of GET compared with control groups (usual care, placebo, placebo exercise, adaptive pacing) was studied in four trials.90,121,125,127 The largest of these was the PACE trial, a 12 month good-quality 4-arm trial that included a comparison of GET (n=159) with adaptive pacing (n=159) and usual care (n=157), and measured outcomes of fatigue (Chalder Fatigue Scale), function (SF-36 physical function subscale), clinical global impression of change, and work impairment (Work and Social Adjustment Scale).121 The CBT arm is discussed in the Cognitive and Behavioral Therapies and Head-to-Head/Combination Therapies Sections. Patients were selected from multiple specialty care centers in the United Kingdom and were eligible based on meeting the Oxford (Sharpe, 1991) criteria as well as having a Chalder Fatigue Scale score of 6 or greater (of possible 11) and SF-36 score of 60 or less (of possible 100) which was subsequently changed to 65 or less to increase enrollment. GET consisted of a maximum of 15 sessions including education and a negotiated exercise plan with incremental activity increases aimed at 30 minutes of light exercise 5 times a week, delivered by physical therapists or exercise physiologists. Adaptive pacing consisted of a maximum of 15 sessions of therapy aimed at achieving optimum adaptation to the illness through activity pacing and advice to avoid activities that demand more than 70 percent of patient’s perceived energy, and was delivered by occupational therapists. Usual care was provided by physicians specializing in ME/CFS. Compared with the usual care group and the adaptive pacing therapy group, at 1 year the GET groups reported statistically significantly better fatigue scores (mean difference GET vs. usual care: −3.2; 95% CI, −4.8 to −1.7; p=0.0003; GET vs. adaptive pacing therapy: −2.5; 95% CI, −4.2 to −0.9; p=0.0059), functioning scores (mean difference GET vs. usual care: 9.4; 95% CI, 4.4 to 14.4; p=0.0005; GET vs. adaptive 12.8; 95% CI, 7.7 to 17.9; p<0.0001), and work impairment scores (mean score: 20.5 GET vs. 23.9 usual care, p<0.001; GET vs. 24.5 adaptive pacing therapy, p<0.001). GET groups reported greater improvement on the self-rated CGI at 1 year compared with both the usual care and adaptive pacing therapy groups (OR of positive change vs. negative change for GET vs. usual care: 2.0; 95% CI, 1.2 to 3.5; p=0.013; GET vs. adaptive pacing therapy: 1.5; 95% CI, 1.0 to 2.3; p=0.028). Improvement was also reported in the 6-minute walk test distance across all groups at 52 weeks but a significantly greater improvement in the GET group (+ 35.3 m, p<0.001 vs. usual care; +41.0 m, p<0.001 vs. adaptive pacing). Symptoms of PEM were lower in the exercise group compared with both usual care (OR 0.5, p=0.003) and adaptive pacing (OR 0.5, p=0.004). The authors performed a sensitivity analysis for those patients who fulfilled the CDC (Reeves, 2003) criteria (n=321) and for those patients who fulfilled the London ME (Dowsett, 1994) criteria (n=245) and found similar results for the outcomes of fatigue and function. The investigators also considered the outcome of recovery, described above in the Counseling and Behavioral Therapies Section.123 Although trial recovery remained low for all treatment arms (<25%), they found GET to be superior to adaptive pacing (OR 3.38; 95% CI, 1.65 to 6.93) and usual care (OR 3.71; 95% CI, 1.78 to 7.74), with similar results for clinical recovery.123 Nonserious adverse events (whether or not related to treatment) were reported often and were similar between groups (usual care: 977; adaptive pacing therapy: 949; GET: 992). Although serious adverse events were uncommon, there were more reported in the GET group (17) than the usual care group (7), p=0.04. Although there was a significant difference in deterioration of physical function across treatment arms (adaptive pacing 25% vs. usual care 18% vs. GET 11%, p<0.001), there were no differences in serious deterioration defined by a composite score of reduced function, worsening clinical global impression, withdrawal rates, and serious adverse reactions due to the treatment.121,122 There were no differences in harms attributable to the treatment received.

As discussed above, the PACE trial may be exposed to risk of observer bias by not blinding the research assessors, and attention bias given the total number of visits by participants were greater in the GET (16) and adaptive pacing (16) groups compared to the usual care group (5). Additionally, patients are educated that they will improve with GET which can add an expectation bias in the direction of improvement.

A smaller fair-quality trial conducted in New Zealand and of shorter duration found similar results on outcomes of fatigue and CGI, but did not find improvement in the physical function subscale of the SF-36. This was a 12-week trial with 6-month followup comparing GET with standard medical care (n=49) and enrolled patients meeting the CDC (Fukuda, 1994) criteria.127 Exercise consisted of treadmill walking starting at 10 to 15 minutes, 4 to 5 times per week at a heart rate of 40 percent of VO_2_ max (50% maximal heart rate) and increased by 3 to 5 minutes per week for the first 6 weeks and then by an increase in heart rate by 5 beats per minute per week with a goal of achieving 30 minutes of exercise at 70 percent VO_2_ maximum (80% maximal heart rate) at 12 weeks.127 The primary outcome was the CGI, which was significantly improved in the GET group compared with the standard medical care group at 12 weeks (55% rated as much or very much better compared with 24% of the control, p=0.04). Sixty-eight percent of patients rated their exercise therapy as ‘effective’ or ‘highly effective.’ Compared with standard therapy, GET showed improvement in all of the secondary fatigue outcomes at 12 weeks (Chalder Fatigue Scale scores; total score: −10.54 vs. −0.94, p=0.02; physical fatigue subscale: −6.64 vs. −0.34, p=0.02; mental fatigue subscale: −3.90 vs. 0.60, p=0.03), but showed no difference in the SF-36 physical functioning subscale (15.95 vs. 9.35, p=0.49). In their intention-to-treat analysis with a 12 percent dropout rate (3 per group), neither the Chalder Fatigue Scale mental fatigue subscale nor SF-36 physical functioning subscale were significant.127 Notably, the GET group was younger (mean age 37 vs. 45 years) and had a shorter duration of illness (2.7 vs. 5.0 years). They received 77 percent of the questionnaires at the 6 month followup and found sustained improvement on the CGI and the Chalder Fatigue Scale physical fatigue whereas the Chalder Fatigue Scale mental fatigue subscale scores showed no difference between groups at 6 months.127 They also considered physiological assessment of fitness with incremental testing on a treadmill to determine maximum aerobic capacity (VO_2_ peak) and found no difference between groups, however, complete data were only available for just over half (65%) the sample as many patients refused to have a second test due to perceived harm from the initial testing (10 of 49, 20%), or stopped prior to maximal effort (5 of 49, 10%), while the equipment failed on two patients.

An earlier fair-quality 12-week trial conducted in the United Kingdom found similar results for CGI, measures of fatigue, and function measured by the SF-36 when comparing GET with flexibility exercises.125 Sixty-six patients fulfilling the Oxford (Sharpe, 1991) criteria and without concurrent psychiatric or insomnia disorders attended weekly sessions in which they were prescribed a home program consisting of either exercise (primarily walking) or stretching and relaxation to be performed 5 days per week. The initial exercise prescription consisted of 5 to 15 minutes of aerobic exercise at an intensity of 40 percent of peak oxygen consumption (50% maximum heart rate) to be increased by 1 or 2 minutes to a maximum of 30 minutes. Once achieved, the intensity was then increased to a maximum of 60 percent of peak oxygen consumption, as monitored by heart rate. If fatigue increased, patients were advised to maintain the same level of exercise until fatigue lessened. The flexibility and relaxation group started at 10 minutes of stretching/relaxation and were advised to increase to a maximum of 30 minutes while avoiding any extra physical activities. A greater number of patients in the GET group reported “much” or “very much” improvement on the CGI (16 of 29, 55% vs. 8 of 30, 27%; p=0.05).125 Intention-to-treat analysis including seven patients who dropped out (4 exercise, 3 flexibility/relaxation) found similar results (17 of 33 vs. 9 of 33, p=0.04). They also evaluated changes in fatigue using various measures and found significant improvement on all measures with the exception of the mental fatigue subscale of the Chalder Fatigue Scale based on differences in means (Chalder Fatigue Scale total score: −8.40 vs. −3,10, p<0.01; VAS total fatigue score [normal=200]: −59 vs. −39, p=0.04; VAS physical fatigue score [normal=100]: −31 vs. −23, p<0.01; VAS mental fatigue score [normal=100]: not significant). Improvement was also noted in function based on SF-36 total scores (137 vs. 84, p=0.05) and physical function score (47.5 vs. 8.0, p=0.01). Although they reported a significant difference in the SF-36 general health score between groups at 12 weeks, there was a difference between the groups at baseline with the change being similar (4.0 vs. 4.0). Differences were also noted in peak oxygen consumption, mean heart rate during submaximal treadmill testing, and mean submaximal perceived exertion score favoring the exercise group (13% vs. 6%; 143 beats per minute, SD 13 vs. 150 beats per minute, SD 13; 14.5, SD 3.4 vs. 16.2, SD 2.8, respectively). Twenty-three of thirty patients in the flexibility/relaxation group were allowed to crossover to the exercise intervention at 12 weeks. One dropped out due to an unrelated condition and of the 22 who completed the program, 54 percent (12 of 22) rated themselves as better. At 1 year they found persistent improvement in measures of function with 66 percent (31 of 47) of those working or studying at least part time compared with only 39 percent (26 of 66) at baseline (95% CI, 9% to 44%).

A final fair-quality 4-arm study (n=136) enrolled 136 patients fulfilling the Oxford (Sharpe, 1991) criteria and compared fluoxetine with GET, placebo, or a combination of GET and fluoxetine, followed them for 6 months, and measured fatigue using the Chalder Fatigue Scale (14-item) and functional capacity measuring the amount of oxygen consumed in the final minute of exercise per kg of body weight.90 Attrition was highest in the combination group (42%), but was also high in the individual intervention groups (32% in fluoxetine group and 29% in GET group), while the control group had lower attrition (17%). Adherence was not reported in considering only the results of the GET (n=34) versus placebo (n=34) arms, after 6 months of treatment there was greater improvement in fatigue (−5.7 vs. −2.7) and more non-cases of fatigue (Chalder score <4) in the exercise interventions (18% vs. 6%). The exercise interventions showed an improvement in functional capacity, with a mean change from baseline at 6 months of 2.8 ml O_2_/kg per minute (95% CI, 0.8 to 4.8). The exercise arm had a greater number of withdrawals compared with placebo (11 of 34, 32% vs. 5 of 34, 15%).

Pooling of three of these trials found a significant improvement in CGI (RR 1.58; 95% CI, 1.25 to 1.98, Figure 4), and SF-36 physical function subscale (weighted mean difference 10.29; 95% CI, 6.71 to 13.88, Figure 5).121,125,127 Due to the variability in how the Chalder Fatigue Scale was used across studies, these results could not be pooled.

Figure 4 Meta-analysis of improvement on CGI scale for exercise compared with controls

* Using adaptive pacing as the comparison

Abbreviations: CGI = Clinical Global Impression of Change Score; CI= confidence interval; N= sample size; RR= relative risk.

Figure 4 is a forest plot of 3 studies reporting improvement on the CGI for exercise versus controls. Data for Figure 4 are presented in Appendix G4, Table 5. This figure is described further in the section on Exercise Programs as follows: “ Pooling of three of these studies found a significant improvement in CGI (RR 1.58; 95% CI, 1.25 to 1.98).”

Figure 5 Meta-analysis of mean changes in SF-36 physical function subscale scores for exercise compared with controls

* Using adaptive pacing as the comparison

Abbreviations: CI= confidence interval; N= sample size; RR= relative risk; SF-36= Short Form 36-item survey.

Figure 5 is a forest plot of 3 studies reporting the weighted mean differences in changes on the SF-36 physical functioning subscale for exercise versus controls. Data for Figure 4 are presented in Appendix G4, Table 5. This figure is described further in the section on Exercise Programs as follows: “Pooling of three of these studies found a significant improvement ... SF-36 physical function subscale (weighted mean difference 10.29; 95% CI, 6.71 to 13.88).”

##### Qigong Exercise

Qigong exercise was compared with no qigong exercise in a 4-month randomized trial in China. Patients 18 to 55 years and meeting the Oxford (Sharpe, 1991) criteria were recruited through online or newspaper advertising in Hong Kong (n=137).129 Those randomized to the exercise group received group qigong twice weekly for 5 weeks (2 hours of education, relaxation, stretching, and 1 hour of qigong training per session) followed by 12 weeks of home based qigong (30 minutes per day). The control group was asked to refrain from qigong exercise. Attrition was 19 percent and similar between groups. Improvement was reported in the Chalder Fatigue Scale total score (mean change: −13.1 vs. −6.6, p<0.001), physical fatigue subscale score (mean change: −8.8 vs. −3.8, p<0.001), and mental fatigue subscale score (mean change: −4.4 vs. −2.8, p=0.01) in both groups with a significantly greater improvement in the qigong exercise group.129 No change was noted in the SF-36 physical function subscale score (3.2 vs. 2.1, p=0.48) in a smaller subgroup that were also being tested for telomerase activity (n=64).126

##### Home Orthostatic Training

Home orthostatic training (40 minutes of standing against a wall with their heels 15 cm from the wall) was compared with a sham home exercise program (10 minutes of wall standing while performing intermittent calf contractions) in a fair-quality 6-month trial of 38 patients fulfilling the CDC (Fukuda, 1994) criteria.128 No differences in fatigue as measured by the fatigue impact score in those who completed the trial and submitted a final questionnaire (n=25). At 6 months, the sham group had a significantly greater drop in blood pressure when standing compared with the intervention group (−6 mmHg; 95% CI, 0.0 to 12.6, p=0.05), but the clinical significance of this was not reported. Of note, they did not perform any subgroup analysis to determine if differences existed in those with subjective autonomic symptoms at baseline.

##### Summary of Exercise Therapies

In summary, compared with control groups, there is moderate strength of evidence that GET improved function (weighted mean difference on SF-36 physical function (10.29; 95% CI, 6.71 to 13.86), and global change scores (RR 1.54; 95% CI, 1.26 to 1.89), and low strength of evidence that GET improved fatigue in ME/CFS patients fulfilling the Oxford (Sharpe, 1991) and/or CDC (Fukuda, 1994) criteria. However, subgroup analysis was inadequate to determine whether these benefits extend to patients with more disability meeting the criteria for ME. Although qigong exercise was found to improve some measures of fatigue, and orthostatic training did not change measures of fatigue, the studies were small and with methodological limitations which leaves uncertainty in the results. Harms were not well reported and although total withdrawal rates were similar in three of four trials, the high rate (20%) of patients refusing repeat exercise testing in one study, limitations in subgroup analysis throughout, and lack of studies using a more disabled population suggest that this outcome has not been adequately studied.

#### Head-to-Head Comparisons and Combination Therapies

Four included trials (8 publications) compared either head-to-head interventions or combinations of two interventions (Table 7 below; Table G4).90,101,105,106,108,111,121 Three trials (in 7 publications) compared head-to-head interventions, one comparing CBT with GET and adaptive pacing and a usual care group,121 one comparing CBT with cognitive therapy and anaerobic activity therapy and relaxation,105,106,108 and one of fluoxetine compared with GET,90 which also had a group of the combination of fluoxetine plus GET for comparison. The fourth trial compared a combination treatment of CBT plus GET with usual care.111 The results for the head-to-head- trials that pertain to the comparison of one intervention to another, not a control group, on outcomes will be discussed in this section; results based on comparisons with control groups, such as GET or CBT were discussed in those previous sections. All trials were designed to target symptoms of ME/CFS, not treat the underlying cause. One trial was good-quality121, while the other three were rated fair-quality90,101,108,111 (Table H2). Three of the trials were of larger size (n>100) and illness duration, when reported, was at least greater than 6 months. Two trials used the Oxford (Sharpe, 1991) criteria to identify patients with CFS,90,121 one used the CDC (Fukuda, 1994) criteria,111 while the other used a combination of a CFS symptom questionnaire, psychiatric assessment, and medical assessment.108

Table 7 Trials of combination therapies for ME/CFS

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Overall Effect Intervention A vs. Intervention B vs. Intervention C, etc.
Jason, et al., 2007^108^ Jason, et al., 2009^106^ Hlavaty, et al., 2011^105^ N=114 Fair Same study as on Table 5 | CFS Questionnaire, psychiatric assessment for DSM-IV diagnosis, and medical assessment | 12 months | A. CBT B. COG C. ACT D. Relaxation | Function: SF-36 physical functioning subscale scores mean (SD): 58.64 (30.44) vs. 61.09 (23.74) vs. 39.72 (27.63) vs. 61.20 (27.70) p<0.01, for CBT and COG over time vs. ACT over time Comparison by energy envelope for those who stayed within envelope vs. outside envelope at 12 months: 65 vs. 43, change at 12 months from baseline: 17 vs. 0; p=0.03 Comparison by homework compliance level, change in score at 12 months from baseline: 6.99 (19.30) vs. 7.55 (18.85) vs. 17.50 (18.09); p=NR % Achieving clinically significant improvement: NS 6 MWT: NS Fatigue: FSS scores mean (SD): 5.37 (1.19) vs. 5.87 (1.01) vs. 5.77 (1.43) vs. 5.62 (1.06); p=NR Comparison by energy envelope for those who stayed within envelope vs. outside envelope at 12 months was 5.3 vs. 6.3 Change at 12 months from baseline: −0.9 vs. 0.1; p<0.01 The comparison by homework compliance level, change in score at 12 months from baseline: −0.17 (0.73) vs. −0.51 (1.00) vs. −0.54 (1.09); p=NR Quality of life: QLS scores mean (SD): 69.10 (18.99) vs. 72.52 (10.84) vs. 63.00 (13.86) vs. 72.00 (19.70); p=NR Employment: % Employed at 12 month followup: NS Harms: Total withdrawals: 25% but not reported per group
Núñez, et al., 2011^111^ N=115 Fair | CDC (Fukuda, 1994) criteria | 2.5–3 months of treatment, 12 months followup after treatment | A. CBT + GET B. Usual care | Function: SF-36 physical function subscale for CBT + GET vs. usual care: NS Fatigue: FIS score for CBT + GET vs. usual care: NS Harms: Not reported
Wearden, et al., 1998^90^ N=136 Fair Same study as on Table 3 and 6 | Oxford (Sharpe, 1991) criteria | 6.5 months (26 weeks) | A. GET + fluoxetine B. GET + drug placebo C. Fluoxetine + exercise placebo D. Placebo control | Function: Functional work capacity based on amount of O_2_ consumed in the final minute of exercise per kg of body weight higher in GET group at 26 weeks, mean change (95% CI) : 2.0 (0.4 to 3.5) vs. 2.8 (0.8 to 4.8) vs. 1.0 (−0.9 to 3.0) vs. −0.1 (−1.7 to 1.6) Effect of exercise on functional work capacity, mean change 0–26 weeks: 1.9 (95% CI 0.15 to 3.69), p=0.03 Fatigue: Chalder Fatigue Scale a, mean change from baseline (95% CI): −6.0 (−9.7 to −2.3 ) vs. −5.7 (−9.5 to −1.9) vs. −3 (−5.9 to −0.2) vs. −2.7 (−5.4 to 0.01) Non-cases of fatigue on Chalder Fatigue Scale (score <4) at 26 weeks: 18% (6/33) vs. 18% (6/34) vs. 6% (2/35) vs. 6% (2/34), p=0.025 for exercise interventions combined vs. others Exercise improved fatigue scale scores: NS Harms: Total withdrawals: greatest in the GET-Fluoxetine arm (42%) vs. Exercise-Drug placebo (32%) vs. Exercise placebo-Fluoxetine (28%) vs. Exercise placebo-Drug placebo (15%)
White, et al., 2011^121^ PACE Trial N=630 Good Same study as on Table 5 and 6 | Oxford (Sharpe, 1991) criteria | 13 months (52 weeks) | A. APT B. CBT C. GET D. Usual care | Function: SF-36 Physical Functions subscale (0–100): CBT vs. GET, p=NS % Improved from baseline (by ≥8 points) was similar in the CBT and GET groups: 49% (75/153) vs. 71% (105/148) vs. 70% (108/154) vs. 58% (88/152) Fatigue: Chalder fatigue scale (0–33) CBT vs. GET, p=NS % Improved from baseline (by ≥2 points) was similar in CBT and GET groups: 65% (99/153) vs. 76% (113/148) vs. 80% (123/154) vs. 65% (98/152) Employment: Work and social adjustment scale scores: CBT vs. GET, p=NS Other: More with positive change in CBT and GET groups on self-rated CGI at 52 weeks: 31% (47/153) vs. 41% (61/147) vs. 41% (62/152) vs. 25% (38/152) Harms: Nonserious adverse events: fewer in CBT group (848) compared with all others (usual care: 977; adaptive pacing therapy: 949; GET: 992), CBT with no serious adverse events versus all others combined (6% vs. 11%, p=.03).

Abbreviations: 6MWT= 6 minute walk test; ACT=anaerobic activity therapy; APT= adaptive pacing therapy; CBT= cognitive behavioral therapy; CDC= Centers for Disease Control and Prevention; CFS= chronic fatigue syndrome; CGI= Clinical Global Impression of Change; CI= confidence interval; COG= cognitive therapy DSM-IV= Diagnostic and Statistical Manual, fourth edition; FIS= Fatigue Impact Scale; FSS= Fatigue Severity Scale; GET= graded exercise therapy; kg= kilogram; N= sample size; NR= not reported; NS= not significant; O_2_= oxygen; QLS= Quality of Life Scale; RR= relative risk SF-36= 36-item Short Form Survey; SD= standard deviation; vs.=versus

Adherence was reported in only one trial, which found that participants completed an average of 10 out of 13 sessions.108 Attrition was reported in three trials and was relatively high (>20%) in one.108 The trial of fluoxetine and GET reported the highest attrition in the combination group (42%), followed by the fluoxetine only group (32%), and the GET only group (29%) in comparison with the lowest in the placebo group (17%).90 The other two trials reported low attrition rates (0.6 to 5%).111,121

There is low strength of evidence that GET and CBT or cognitive therapy had similar results on measures of fatigue and function in one good-quality and two fair-quality head-to-head trials. GET was superior to fluoxetine on measures of fatigue and function in one fair-quality trial but represents an insufficient strength of evidence given that it was a single study of small sample size. Harms were not well reported leaving insufficient evidence, however patients receiving GET reported more adverse events compared with CBT, adaptive pacing, or usual care in one good-quality trial, and fewer patients in the CBT group reported having serious adverse events versus all others combined (6% vs. 11%, p=.03).121

The PACE trial described previously was a large 12-month good-quality trial (n=641) comparing four interventions: CBT, GET, an adaptive pacing therapy, and a usual care control group.121 Attrition was low with only 1.7 percent withdrawing overall and adherence was not reported. Compared with the control and adaptive pacing groups, at 1 year the CBT and GET groups reported similar improvement in fatigue scores, functioning scores, and work impairment scores. Both CBT and GET groups reported greater improvement on the self-rated CGI at 1 year compared with both the control and adaptive pacing therapy groups (OR of positive change vs. negative change for CBT vs. control: 2.2; 95% CI, 1.2 to 3.9; p=0.011; CBT vs. adaptive pacing therapy: 1.7; 95% CI, 1.0 to 2.7; p=0.034; GET vs. control: 2.0; 95% CI, 1.2 to 3.5; p-0.013; GET vs. adaptive pacing therapy: 1.5; 95% CI, 1.0 to 2.3; p-0.028). Similar results for fatigue and function were found when the data were reanalyzed for those patients fulfilling the CDC (Reeves, 2003) criteria (n=427), and London (Dowsett, 1994) criteria (n=329). The investigators also considered the outcome of recovery (trial and clinical recovery described earlier).123 They found no difference between CBT (32 of 143, 22%) and GET (32 of 143, 22%), both of which were better than adaptive pacing (12 of 149, 8%) and usual care (11 of 150, 7%).123 Harms were reported as nonserious and serious adverse events, serious adverse reactions attributed to the treatment, and serious deterioration. Nonserious adverse events were reported often; however, the CBT group reported fewer events (848) compared with all groups (usual care: 977; adaptive pacing therapy: 949; GET: 992), and fewer patients in the CBT group reported having serious adverse events versus all others combined (6% vs. 11%, p=.03).122 A post-hoc analysis revealed that frequency of nonserious adverse event reporting was associated with the center at which the patient was seen. When adjusted for center, factors affecting the reporting of a nonserious adverse event included baseline CFS symptom count (OR 1.12; 95% CI, 1.01 to 1.24, p=0.03), baseline current depressive disorder (OR 1.47; 95% CI, 1.04 to 2.07), and log body mass index (OR 2.55; 95% CI, 1.09 to 5.96, p=0.03).122 Serious adverse reactions attributed to the treatment were rare, and although more were reported by the GET group (17) compared with all groups (control: 7; adaptive pacing therapy: 16; CBT: 8), this was not statistically significant. The limitations of this study have already been extensively reviewed in the section on Counseling and Behavioral Therapies.

A fair-quality trial (n=114) compared CBT with cognitive therapy, with an anaerobic activity therapy, and with a relaxation techniques control group; this study followed participants for 12 months and measured fatigue using the FSS, quality of life using the QLS, functioning using the SF-36 physical functioning subscale, and employment status.108 Overall 25 percent of individuals dropped out (not reported per group) and individuals attended an average of 10 out of 13 sessions. At 12 months the CBT group and the cognitive therapy group had statistically significantly better functioning scores compared with the anaerobic activity therapy group (mean scores: 58.64 vs. 61.09 vs. 39.72; p<0.01). There were no differences in employment status, fatigue scores, 6-minute walk test, or quality of life scores, and harms were not reported. Most continued to meet the criteria for CFS at completion and there were no significant differences between groups.

Fluoxetine and/or GET were compared in a previously described trial with 6-month measurements of fatigue (Chalder Fatigue Scale) and functional capacity measuring the amount of oxygen consumed in the final minute of exercise per kg of body weight.90 GET was superior to fluoxetine and/or placebo on all measures. Total withdrawal was greatest in the GET group compared with the nonexercise groups (37% vs. 22%). The other combination trial was a fair-quality trial (n=120) that compared group CBT and group GET with a usual care control group; this study followed participants for 12 months and measured fatigue using the FIS and function using the SF-36 physical functioning subscale.111 Adherence was not reported, but attrition was low overall (4.2%). Neither fatigue nor functioning scores were significantly different at 12 months followup and harms were not reported.

In summary, head-to-head trials had mixed results. Functional improvement with CBT and GET, as well as CBT and cognitive therapy appear similar and better than control groups.108,121 Fatigue may be similar between CBT and GET, and better than control groups as noted in one large trial121 but one trial of CBT plus GET found no difference compared with the control.111 In considering non-head-to-head trial data, CBT and GET provided similar improvement in measures of function and possibly fatigue, while the evidence was insufficient for other outcomes and comparisons. No study used a case definition selecting for more disabled patients and subgroup analysis of patients with PEM or cognitive impairment was lacking; these factors limit interpretation of the overall results. GET was superior to fluoxetine but the strength of evidence is insufficient, given that this comparison was only studied in one small fair-quality trial. Harms were again poorly reported and have not been adequately studied in subgroups with PEM or more severely disabled patients. When reported, harms of CBT appear to be less than with GET.

## Key Question 2c What are the characteristics of responders and nonresponders to interventions?

### Key Points

- Evidence on patient characteristics associated with response/nonresponse to treatment was insufficient—evidence was limited to four small fair-quality trials that considered different characteristics.
- One trial found that those who had lower functional impairment, less fatigue, and less pain at baseline were more likely to improve after group CBT.
- One trial found that younger patients with shorter illness durations and less severe mobility problems at baseline responded better.
- One trial found that a reduction in symptom focusing was associated with improvement in self-reported measures of function, fatigue, and global improvement.
- One trial found that patients who avoided over or under exertion (stayed within their energy envelope) and had 75 percent or better compliance with their home program had improvement in fatigue and function measures.

### Detailed Synthesis

Four trials contribute to the understanding of characteristics of patients more likely to respond to therapies for ME/CFS. Results of these studies suggest that younger patients with less impairment, have less symptom focusing, and are compliant with homework are more likely to improve in some measures of fatigue and/or function.100,105,106,119,127 Staying within one’s energy envelope also appeared beneficial; however, evidence for these factors is insufficient to determine its applicability to all patients with ME/CFS.

One fair-quality trial described above100 compared group CBT with a wait list control and conducted a separate analysis to compare the baseline measures of those who improved with group CBT (n=10) and those who did not improve (n=17) at 6 months (Table G4). Those who improved were more likely to have less functional impairment on the SIP-8 (1,330 vs. 1,985; p=0.031), less daily self-rated observed fatigue on the Chalder Fatigue Scale (7.4 vs. 9.7 on a scale of 0 to 11; p=0.023), and less daily self-rated observed pain (4.5 vs. 7.8; p=0.026) compared with those who did not improve with group CBT. Though the difference did not reach statistical significance, those who improved were more likely to be working more hours per week compared with those who did not improve (10.9 vs. 2.6; p=0.062). There were no differences between those who improved on group CBT and those who did not on baseline measures of age, education, duration of illness, CIS fatigue score, psychological distress, depression, physical attributes, self-efficacy, avoidance of activity, and focusing on bodily symptoms.

One trial comparing GET with usual care127 performed multiple regression analysis to determine possible cognitive or physiological mediators affecting response to GET. This study found that self-reported improvement in mental and physical fatigue, global change, and physical functioning in the exercise group were all associated with a reduction in symptom focusing.127 Critical to this analysis, however, is that patients in the exercise group were also instructed in ways to reduce symptom focusing and to attend to the heart rate monitor for feedback as to whether their activity level was safe or not. This places an expectation bias into the results.

One trial conducted post hoc analyses to determine which factors may predict change on the Chalder Fatigue Scale in patients who received pragmatic rehabilitation. This study found significant effect for age (−0.10; 95% CI, −0.19 to −0.003; p=0.044), duration of illness (−0.01; 95% CI, −0.02 to −0.003; p=0.008), and severity as measured by the EQ-5D mobility scale (−2.95; 95% CI, −5.51 to −0.40; p=0.024). Those who were younger, had shorter illness durations, and less severe mobility problems at baseline showed greater improvements in fatigue at 70 weeks.119

One trial conducted post hoc analyses based on whether or not individuals stayed within their energy envelope, meaning they avoided overexertion and under exertion by exerting a comfortable range of energy, or strayed outside their energy envelope.106 Individuals rated their perceived energy and expended energy and this was used to determine which individuals stayed within their energy envelope (n=49) and which were outside their energy envelope (n=32). At 12 months there was a statistically significant improvement in mean fatigue and functioning scores from baseline for those who stayed within their energy envelope compared with those who were outside their energy envelope (fatigue scores: −0.9 vs. 0.1; p<0.01 and functioning scores: 17 vs. 0; p=0.03). The second additional analysis compared fatigue and functioning outcomes based on homework compliance.105 The researchers identified three groups based on the amount of homework completed; minimum compliance completed 0 to 25 percent, moderate compliance completed 25.1 to 75 percent, and maximum compliance completed 75.1 to 100 percent of their assigned homework. When they assigned individuals to groups they noted that the highest percentage in the maximum group (56%) were in the cognitive therapy group, the highest percentage in the moderate group (34%) were in the CBT group, and the highest percentage in the minimum group (38%) were in the anaerobic and relaxation groups. At 12 months, though there was a trend toward better improvement in fatigue and functioning scores for the maximum compliance group compared with the other groups, this did not reach significance.

No other studies evaluated characteristics of responders and nonresponders to interventions.