# References

1 Friedberg F, Bateman L, Bested AC, et al. (2014). ME/CFS: A primer for clinical practitioners.
2 Carruthers BM, Jain AK, de Meirleir KL, et al. (2003). Myalgic Encephalomyelitis/Chronic Fatigue Syndrome: Clinical Working Case Definition, Diagnostic and Treatment Protocols. J Chronic Fatigue Syndr.
3 Carruthers BM, van de Sande MI, De Meirleir KL, et al. (2011). Myalgic encephalomyelitis: International Consensus Criteria. J Intern Med.
4 Fukuda K, Straus SE, Hickie I, et al. (1994). The chronic fatigue syndrome: a comprehensive approach to its definition and study. International Chronic Fatigue Syndrome Study Group. Ann Intern Med.
5 Jason LA, Brown A, Evans M, et al. (2013). Contrasting chronic Fatigue syndrome versus myalgic encephalomyelitis/chronic fatigue syndrome. Fatigue.
6 Davenport TE, Stevens SR, VanNess MJ, et al. (2010). Conceptual model for physical therapist management of chronic fatigue syndrome/myalgic encephalomyelitis. Phys Ther.
7 Carruthers BM, van de Sande MI, De Meirleir K, et al. (2012). Myalgic Encephalomyelitis – Adult & Paediatric: International Consensus Primer for Medical Practitioners.
8 Hooper M. (2007). Myalgic encephalomyelitis: a review with emphasis on key findings in biomedical research. J Clin Pathol.
9 Jason LA, Brown A, Clyne E, et al. (2012). Contrasting case definitions for chronic fatigue syndrome, Myalgic Encephalomyelitis/chronic fatigue syndrome and myalgic encephalomyelitis. Eval Health Prof.
10 Holmes GP, Kaplan JE, Gantz NM, et al. (1988). Chronic fatigue syndrome: a working case definition. Ann Intern Med.
11 Ramsay M. (1986). Myalgic Encephalomyelitis and Postviral Fatigue States: The saga of Royal Free disease.
12 (1956). A NEW CLINICAL entity?. Lancet.
13 Jason LA, Taylor RR, Plioplys S, et al. (2002). Evaluating attributions for an illness based upon the name: chronic fatigue syndrome, myalgic encephalopathy and Florence Nightingale disease. Am J Community Psychol.
14 Jason LA, Taylor RR, Stepanek Z, et al. (2001). Attitudes regarding chronic fatigue syndrome: The importance of a name. J Health Psychol.
15 Komaroff AL, Cho TA. (2011). Role of infection and neurologic dysfunction in chronic fatigue syndrome. Semin Neurol.
16 Morris G, Maes M. (2013). A neuro-immune model of Myalgic Encephalomyelitis/Chronic fatigue syndrome. Metab Brain Dis.
17 Hempel S, Chambers D, Bagnall AM, et al. (2008). Risk factors for chronic fatigue syndrome/myalgic encephalomyelitis: a systematic scoping review of multiple predictor studies. Psychol Med.
18 Afari N, Buchwald D. (2003). Chronic fatigue syndrome: a review. Am J Psychiatry.
19 Chew-Graham C, Dowrick C, Wearden A, et al. (2010). Making the diagnosis of Chronic Fatigue Syndrome/Myalgic Encephalitis in primary care: a qualitative study. BMC Fam Pract.
20 Anderson G, Maes M, Berk M. (2012). Biological underpinnings of the commonalities in depression, somatization, and Chronic Fatigue Syndrome. Med Hypotheses.
21 Reyes M, Nisenbaum R, Hoaglin DC, et al. (2003). Prevalence and incidence of chronic fatigue syndrome in Wichita, Kansas. Arch Intern Med.
22 Reeves WC, Jones JF, Maloney E, et al. (2007). Prevalence of chronic fatigue syndrome in metropolitan, urban, and rural Georgia. Popul Health Metr.
23 Johnston S, Brenu EW, Staines D, et al. (2013). The prevalence of chronic fatigue syndrome/myalgic encephalomyelitis: a meta-analysis. Clin Epidemiol.
24 Rangel L, Garralda ME, Levin M, et al. (2000). The course of severe chronic fatigue syndrome in childhood. J R Soc Med.
25 Crawley EM, Emond AM, Sterne JA. (2011). Unidentified Chronic Fatigue Syndrome/myalgic encephalomyelitis (CFS/ME) is a major cause of school absence: surveillance outcomes from school-based clinics. BMJ Open.
26 Centers for Disease Control and Prevention. Chronic Fatigue Syndrome (CFS) in Children and Adolescents.
27 Jason LA, Porter N, Hunnell J, et al. (2011). A natural history study of chronic fatigue syndrome. Rehabil Psychol.
28 Adamowicz JL, Caikauskaite I, Friedberg F. (2014). Defining recovery in chronic fatigue syndrome: a critical review. Qual Life Res.
29 Cairns R, Hotopf M. (2005). A systematic review describing the prognosis of chronic fatigue syndrome. Occup Med.
30 Center for Drug Evaluation and Research. (2013). The Voice of the Patient: A series of reports from the U.S. Food and Drug Administration’s (FDA’s) Patient-Focused Drug Development Initiative. Chronic Fatigue Syndrome and Myalgic Encephalomyelitis.
31 (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
32 Smith MEB, Nelson N, Haney E, et al. Diagnosis and treatment of myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS). PROSPERO 2014:CRD42014009779 2014.
33 Altman DG, Bland JM. (1994). Diagnostic tests 3: receiver operating characteristic plots. BMJ.
34 Zweig MH, Campbell G. (1993). Receiver-operating characteristic (ROC) plots: a fundamental evaluation tool in clinical medicine. Clin Chem.
35 Hosmer DW, Lemeshow S. (2004). Applied logistic regression.
36 Pemberton S, Hatcher S, Stanley P, et al. (1994). Chronic fatigue syndrome: A way forward. The British Journal of Occupational Therapy.
37 Nisenbaum R, Jones JF, Unger ER, et al. (2003). A population-based study of the clinical course of chronic fatigue syndrome. Health Qual Life Outcomes.
38 (2012). Methods Guide for Medical Test Reviews.
39 Whiting PF, Rutjes AWS, Westwood ME, et al. (2011). QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Ann Intern Med.
40 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
41 Atkins D, Chang SM, Gartlehner G, et al. (2011). Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
42 Fu R, Gartlehner G, Grant M, et al. (2011). Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
43 Sutton A, Abrams K, Jones DR, et al. (2000). Methods for Meta-Analysis in Medical Research.
44 Higgins JP, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
45 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
46 Sharpe MC, Archard LC, Banatvala JE, et al. (1991). A report--chronic fatigue syndrome: guidelines for research. J R Soc Med.
47 Dowsett E, Goudsmit E, Macintyre A, et al. (1994). Report from The National Task Force on Chronic Fatigue Syndrome (CFS), Post Viral Fatigue Syndrome (PVFS), Myalgic Encephalomyelitis (ME). Westcare.
48 Jason L, Evans M, Porter N, et al. (2010). The Development of a Revised Canadian Myalgic Encephalomyelitis Chronic Fatigue Syndrome Case Definition. Am J Biochem Biotechnol.
49 Reeves WC, Wagner D, Nisenbaum R, et al. (2005). Chronic fatigue syndrome--a clinically empirical approach to its definition and study. BMC Med.
50 Jason LA, Torres-Harding SR, Taylor RR, et al. (2001). A comparison of the 1988 and 1994 diagnostic criteria for chronic fatigue syndrome. J Clin Psychol Med Settings.
51 Brown AA, Jason LA, Evans MA, et al. (2013). Contrasting case definitions: The ME International Consensus Criteria vs. the Fukuda et al. CFS criteria. N Am J Psychol.
52 Van Hoof E, De Meirleir K. (2005). Chronic Fatigue Syndrome and Myalgic Encephalomyletis: Are Both Conditions on the Same Continuum?. N Am J Psychol.
53 Lewis I, Pairman J, Spickett G, et al. (2013). Is chronic fatigue syndrome in older patients a different disease? -- a clinical cohort study. Eur J Clin Invest.
54 Jason LA, Sunnquist M, Brown A, et al. (2014). Are Myalgic Encephalomyelitis and chronic fatigue syndrome different illnesses? A preliminary analysis. J Health Psychol.
55 Jason LA, Torres-Harding SR, Jurgens A, et al. (2004). Comparing the Fukuda et al. criteria and the Canadian case definition for chronic fatigue syndrome. J Chronic Fatigue Syndr.
56 Jason LA, Evans M, Brown A, et al. (2010). Sensitivity and specificity of the CDC empirical chronic fatigue syndrome case definition. Psychology.
57 Aslakson E, Vollmer-Conna U, White PD. (2006). The validity of an empirical delineation of heterogeneity in chronic unexplained fatigue. Pharmacogenomics.
58 Katon WJ, Buchwald DS, Simon GE, et al. (1991). Psychiatric illness in patients with chronic fatigue and those with rheumatoid arthritis. J Gen Intern Med.
59 Komaroff AL, Fagioli LR, Doolittle TH, et al. (1996). Health status in patients with chronic fatigue syndrome and in general population and disease comparison groups. Am J Med.
60 Davenport TE, Stevens SR, Baroni K, et al. (2011). Reliability and validity of Short Form 36 Version 2 to measure health perceptions in a sub-group of individuals with fatigue. Disabil Rehabil.
61 Davenport TE, Stevens SR, Baroni K, et al. (2011). Diagnostic accuracy of symptoms characterising chronic fatigue syndrome. Disabil Rehabil.
62 Tiev KP, Demettre E, Ercolano P, et al. (2003). RNase L levels in peripheral blood mononuclear cells: 37-kilodalton/83-kilodalton isoform ratio is a potential test for chronic fatigue syndrome. Clin Diagn Lab Immunol.
63 Linder R, Dinser R, Wagner M, et al. (2002). Generation of classification criteria for chronic fatigue syndrome using an artificial neural network and traditional criteria set. In Vivo.
64 Hadzi-Pavlovic D, Hickie IB, Wilson AJ, et al. (2000). Screening for prolonged fatigue syndromes: validation of the SOFA scale. Soc Psychiatry Psychiatr Epidemiol.
65 Jason L, Brown M, Evans M, et al. (2011). Measuring substantial reductions in functioning in patients with chronic fatigue syndrome. Disabil Rehabil.
66 Gaab J, Engert V, Heitz V, et al. (2004). Associations between neuroendocrine responses to the Insulin Tolerance Test and patient characteristics in chronic fatigue syndrome. J Psychosom Res.
67 Gaab J, Huster D, Peisen R, et al. (2002). Low-dose dexamethasone suppression test in chronic fatigue syndrome and health. Psychosom Med.
68 Gaab J, Rohleder N, Heitz V, et al. (2005). Stress-induced changes in LPS-induced pro-inflammatory cytokine production in chronic fatigue syndrome. Psychoneuroendocrinology.
69 Watson SP, Ruskin AS, Simonis V, et al. (2014). Identifying Defining Aspects of Chronic Fatigue Syndrome via Unsupervised Machine Learning and Feature Selection. International Journal of Machine Learning & Computing.
70 Jason LA, Taylor RR. (2001). Measuring attributions about chronic fatigue syndrome. J Chronic Fatigue Syndr.
71 Asbring P, Narvanen A-L. (2002). Women’s experiences of stigma in relation to chronic fatigue syndrome and fibromyalgia. Qual Health Res.
72 Assefi NP, Coy TV, Uslan D, et al. (2003). Financial, occupational, and personal consequences of disability in patients with chronic fatigue syndrome and fibromyalgia compared to other fatiguing conditions. J Rheumatol.
73 Deale A, Wessely S. (2000). Diagnosis of psychiatric disorder in clinical evaluation of chronic fatigue syndrome. J R Soc Med.
74 Dickson A, Knussen C, Flowers P. (2007). Stigma and the delegitimation experience: An interpretative phenomenological analysis of people living with chronic fatigue syndrome. Psychol Health.
75 Green J, Romei J, Natelson BH. (1999). Stigma and chronic fatigue syndrome. J Chronic Fatigue Syndr.
76 Guise J, McVittie C, McKinlay A. (2010). A discourse analytic study of ME/CFS (Chronic Fatigue Syndrome) sufferers’ experiences of interactions with doctors. J Health Psychol.
77 Brimmer DJ, Maloney E, Devlin R, et al. (2013). A pilot registry of unexplained fatiguing illnesses and chronic fatigue syndrome. BMC Res Notes.
78 Devasahayam A, Lawn T, Murphy M, et al. (2012). Alternative diagnoses to chronic fatigue syndrome in referrals to a specialist service: service evaluation survey. JRSM short reports.
79 Lawn T, Kumar P, Knight B, et al. (2010). Psychiatric misdiagnoses in patients with chronic fatigue syndrome. JRSM short reports.
80 Newton JL, Mabillard H, Scott A, et al. (2010). The Newcastle NHS Chronic Fatigue Syndrome Service: not all fatigue is the same. J R Coll Physicians Edinb.
81 Woodward RV, Broom DH, Legge DG. (1995). Diagnosis in chronic illness: disabling or enabling--the case of chronic fatigue syndrome. J R Soc Med.
82 Blacker CVR, Greenwood DT, Wesnes KA, et al. (2004). Effect of galantamine hydrobromide in chronic fatigue syndrome: a randomized controlled trial. JAMA.
83 McKenzie R, O’Fallon A, Dale J, et al. (1998). Low-dose hydrocortisone for treatment of chronic fatigue syndrome: a randomized controlled trial. JAMA.
84 Blockmans D, Persoons P, Van Houdenhove B, et al. (2003). Combination therapy with hydrocortisone and fludrocortisone does not improve symptoms in chronic fatigue syndrome: a randomized, placebo-controlled, double-blind, crossover study. Am J Med.
85 Peterson PK, Shepard J, Macres M, et al. (1990). A controlled trial of intravenous immunoglobulin G in chronic fatigue syndrome. Am J Med.
86 Montoya JG, Kogelnik AM, Bhangoo M, et al. (2013). Randomized clinical trial to evaluate the efficacy and safety of valganciclovir in a subset of patients with chronic fatigue syndrome. J Med Virol.
87 Strayer DR, Carter WA, Brodsky I, et al. (1994). A controlled clinical trial with a specifically configured RNA drug, poly(I) midline dot poly(C12U), in chronic fatigue syndrome. Clin Infect Dis.
88 Strayer DR, Carter WA, Stouch BC, et al. (2012). A double-blind, placebo-controlled, randomized, clinical trial of the TLR-3 agonist rintatolimod in severe cases of chronic fatigue syndrome. PLoS ONE.
89 Diaz-Mitoma F, Turgonyi E, Kumar A, et al. (2003). Clinical improvement in chronic fatigue syndrome is associated with enhanced natural killer cell-mediated cytotoxicity: The results of a pilot study with Isoprinosine. J Chronic Fatigue Syndr.
90 Wearden AJ, Morriss RK, Mullis R, et al. (1998). Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome. Br J Psychiatry.
91 Straus SE, Dale JK, Tobi M, et al. (1988). Acyclovir treatment of the chronic fatigue syndrome. Lack of efficacy in a placebo-controlled trial. N Engl J Med.
92 Fluge O, Bruland O, Risa K, et al. (2011). Benefit from B-lymphocyte depletion using the anti-CD20 antibody rituximab in chronic fatigue syndrome. A double-blind and placebo-controlled study. PLoS ONE.
93 Hobday RA, Thomas S, O’Donovan A, et al. (2008). Dietary intervention in chronic fatigue syndrome. J Hum Nutr Diet.
94 Öckerman PA. (2000). Antioxidant treatment of chronic fatigue syndrome. Clin Pract Alternat Med.
95 The GKH, Bleijenberg G, van der Meer JWM. (2007). The effect of acclydine in chronic fatigue syndrome: A randomized controlled trial. PLoS Clinical Trials.
96 Vermeulen RCW, Scholte HR. (2004). Exploratory open label, randomized study of acetyl- and propionylcarnitine in chronic fatigue syndrome. Psychosom Med.
97 Walach H, Bosch H, Lewith G, et al. (2008). Effectiveness of distant healing for patients with chronic fatigue syndrome: a randomised controlled partially blinded trial (EUHEALS). Psychother Psychosom.
98 Weatherley-Jones E, Nicholl JP, Thomas KJ, et al. (2004). A randomised, controlled, triple-blind trial of the efficacy of homeopathic treatment for chronic fatigue syndrome. J Psychosom Res.
99 Williams G, Waterhouse J, Mugarza J, et al. (2002). Therapy of circadian rhythm disorders in chronic fatigue syndrome: no symptomatic improvement with melatonin or phototherapy. Eur J Clin Invest.
100 Bazelmans E, Prins JB, Lulofs R, et al. (2005). Cognitive behaviour group therapy for chronic fatigue syndrome: a non-randomised waiting list controlled study. Psychother Psychosom.
101 Burgess M, Andiappan M, Chalder T. (2012). Cognitive behaviour therapy for chronic fatigue syndrome in adults: face to face versus telephone treatment: a randomized controlled trial. Behav Cogn Psychother.
102 Deale A, Chalder T, Marks I, et al. (1997). Cognitive behavior therapy for chronic fatigue syndrome: a randomized controlled trial. Am J Psychiatry.
103 Deale A, Husain K, Chalder T, et al. (2001). Long-term outcome of cognitive behavior therapy versus relaxation therapy for chronic fatigue syndrome: a 5-year follow-up study. Am J Psychiatry.
104 Goudsmit EM, Ho-Yen DO, Dancey CP. (2009). Learning to cope with chronic illness. Efficacy of a multi-component treatment for people with chronic fatigue syndrome. Patient Educ Couns.
105 Hlavaty LE, Brown MM, Jason LA. (2011). The effect of homework compliance on treatment outcomes for participants with myalgic encephalomyelitis/chronic fatigue syndrome. Rehabil Psychol.
106 Jason L, Benton M, Torres-Harding S, et al. (2009). The impact of energy modulation on physical functioning and fatigue severity among patients with ME/CFS. Patient Educ Couns.
107 Jason LA, Roesner N, Porter N, et al. (2010). Provision of social support to individuals with chronic fatigue syndrome. J Clin Psychol.
108 Jason LA, Torres-Harding S, Friedberg F, et al. (2007). Non-pharmacologic interventions for CFS: a randomized trial. J Clin Psychol Med Settings.
109 Knoop H, van der Meer JWM, Bleijenberg G. (2008). Guided self-instructions for people with chronic fatigue syndrome: randomised controlled trial. Br J Psychiatry.
110 Lopez C, Antoni M, Penedo F, et al. (2011). A pilot study of cognitive behavioral stress management effects on stress, quality of life, and symptoms in persons with chronic fatigue syndrome. J Psychosom Res.
111 Núñez M, Fernandez-Sola J, Núñez E, et al. (2011). Health-related quality of life in patients with chronic fatigue syndrome: group cognitive behavioural therapy and graded exercise versus usual treatment. A randomised controlled trial with 1year of follow-up. Clin Rheumatol.
112 O’Dowd H, Gladwell P, Rogers CA, et al. (2006). Cognitive behavioural therapy in chronic fatigue syndrome: a randomised controlled trial of an outpatient group programme. Health Technol Assess.
113 Sharpe M, Hawton K, Simkin S, et al. (1996). Cognitive behaviour therapy for the chronic fatigue syndrome: a randomized controlled trial. BMJ.
114 Taylor RR. (2004). Quality of life and symptom severity for individuals with chronic fatigue syndrome: findings from a randomized clinical trial. Am J Occup Ther.
115 Tummers M, Knoop H, Bleijenberg G. (2010). Effectiveness of stepped care for chronic fatigue syndrome: a randomized noninferiority trial. J Consult Clin Psychol.
116 Tummers M, Knoop H, van Dam A, et al. (2012). Implementing a minimal intervention for chronic fatigue syndrome in a mental health centre: a randomized controlled trial. Psychol Med.
117 Tummers M, Knoop H, van Dam A, et al. (2013). Moderators of the treatment response to guided self-instruction for chronic fatigue syndrome. J Psychosom Res.
118 Wearden AJ, Dowrick C, Chew-Graham C, et al. (2010). Nurse led, home based self help treatment for patients in primary care with chronic fatigue syndrome: randomised controlled trial. BMJ.
119 Wearden AJ, Dunn G, Dowrick C, et al. (2012). Depressive symptoms and pragmatic rehabilitation for chronic fatigue syndrome. Br J Psychiatry.
120 Wearden AJ, Emsley R. (2013). Mediators of the effects on fatigue of pragmatic rehabilitation for chronic fatigue syndrome. J Consult Clin Psychol.
121 White PD, Goldsmith KA, Johnson AL, et al. (2011). Comparison of adaptive pacing therapy, cognitive behaviour therapy, graded exercise therapy, and specialist medical care for chronic fatigue syndrome (PACE): a randomised trial. Lancet.
122 Dougall D, Johnson A, Goldsmith K, et al. (2014). Adverse events and deterioration reported by participants in the PACE trial of therapies for chronic fatigue syndrome. J Psychosom Res.
123 White PD, Goldsmith K, Johnson AL, et al. (2013). Recovery from chronic fatigue syndrome after treatments given in the PACE trial. Psychol Med.
124 Troosters T, Gosselink R, Decramer M. (1999). Six minute walking distance in healthy elderly subjects. The European respiratory journal.
125 Fulcher KY, White PD. (1997). Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ.
126 Ho RTH, Chan JSM, Wang C-W, et al. (2012). A randomized controlled trial of qigong exercise on fatigue symptoms, functioning, and telomerase activity in persons with chronic fatigue or chronic fatigue syndrome. Ann Behav Med.
127 Moss-Morris R, Sharon C, Tobin R, et al. (2005). A randomized controlled graded exercise trial for chronic fatigue syndrome: outcomes and mechanisms of change. J Health Psychol.
128 Sutcliffe K, Gray J, Tan MP, et al. (2010). Home orthostatic training in chronic fatigue syndrome--a randomized, placebo-controlled feasibility study. Eur J Clin Invest.
129 Chan JSM, Ho RTH, Wang CW, et al. (2013). Effects of qigong exercise on fatigue, anxiety, and depressive symptoms of patients with chronic fatigue syndrome-like illness: A randomized controlled trial. Evidence based Complementary and Alternative Medicine.
130 Scadding JG. (1967). Diagnosis: the clinician and the computer. Lancet.
131 Brurberg KG, Fonhus MS, Larun L, et al. (2014). Case definitions for chronic fatigue syndrome/myalgic encephalomyelitis (CFS/ME): a systematic review. BMJ Open.
132 Vanness JM, Snell CR, Strayer DR, et al. (2003). Subclassifying chronic fatigue syndrome through exercise testing. Med Sci Sports Exerc.
133 Sisto SA, LaManca J, Cordero DL, et al. (1996). Metabolic and cardiovascular effects of a progressive exercise test in patients with chronic fatigue syndrome. Am J Med.
134 Biswal B, Kunwar P, Natelson BH. (2011). Cerebral blood flow is reduced in chronic fatigue syndrome as assessed by arterial spin labeling. J Neurol Sci.
135 Boda WL, Natelson BH, Sisto SA, et al. (1995). Gait abnormalities in chronic fatigue syndrome. J Neurol Sci.
136 Frith J, Zalewski P, Klawe JJ, et al. (2012). Impaired blood pressure variability in chronic fatigue syndrome--a potential biom arker. QJM.
137 Naschitz JE, Sabo E, Naschitz S, et al. (2002). Hemodynamics instability score in chronic fatigue syndrome and in non-chronic fatigue syndrome. Semin Arthritis Rheum.
138 Jones DEJ, Hollingsworth KG, Jakovljevic DG, et al. (2012). Loss of capacity to recover from acidosis on repeat exercise in chronic fatigue syndrome: a case-control study. Eur J Clin Invest.
139 Huibers MJ, Wessely S. (2006). The act of diagnosis: pros and cons of labelling chronic fatigue syndrome. Psychol Med.
140 Komaroff AL, Buchwald DS. (1998). Chronic fatigue syndrome: an update. Annu Rev Med.
141 Komaroff AL. (2006). Is human herpesvirus-6 a trigger for chronic fatigue syndrome?. J Clin Virol.
142 Devanur LD, Kerr JR. (2006). Chronic fatigue syndrome. J Clin Virol.
143 Lloyd A, Hickie I, Wakefield D, et al. (1990). A double-blind, placebo-controlled trial of intravenous immunoglobulin therapy in patients with chronic fatigue syndrome. Am J Med.
144 Chambers D, Bagnall A-M, Hempel S, et al. (2006). Interventions for the treatment, management and rehabilitation of patients with chronic fatigue syndrome/myalgic encephalomyelitis: an updated systematic review. J R Soc Med.
145 Whiting P, Bagnall AM, Sowden AJ, et al. (2001). Interventions for the treatment and management of chronic fatigue syndrome: a systematic review. JAMA.
146 Alraek T, Lee MS, Choi T-Y, et al. (2011). Complementary and alternative medicine for patients with chronic fatigue syndrome: a systematic review. BMC Altern Med.
147 Kim J-E, Hong K-E, Kim H-J, et al. (2013). An open-label study of effects of acupuncture on chronic fatigue syndrome and idiopathic chronic fatigue: study protocol for a randomized controlled trial. Trials.
148 Brown AA, Evans MA, Jason LA. (2013). Examining the energy envelope and associated symptom patterns in chronic fatigue syndrome: Does coping matter?. Chronic Illn.
149 Cooper L. (2000). Report on Survey of Members of Local ME Groups.
150 Edmonds M, McGuire H, Price J. (2004). Exercise therapy for chronic fatigue syndrome. Cochrane Database Syst Rev.
151 Snell CR, Vanness JM, Strayer DR, et al. (2005). Exercise capacity and immune function in male and female patients with chronic fatigue syndrome (CFS). In Vivo.
152 Snell CR, Stevens SR, Davenport TE, et al. (2013). Discriminative validity of metabolic and workload measurements for identifying people with chronic fatigue syndrome. Phys Ther.
153 Fu Q, Vangundy TB, Galbreath MM, et al. (2010). Cardiac origins of the postural orthostatic tachycardia syndrome. Journal of the American College of Cardiology.
154 Goldner F, Jacob G, Raj SR, et al. (2006). The importance of recognizing postural pseudoanemia. Compr Ther.
155 Hastings JL, Krainski F, Snell PG, et al. (2012). Effect of rowing ergometry and oral volume loading on cardiovascular structure and function during bed rest. J Appl Physiol (1985).
156 Jeong SM, Shibata S, Levine BD, et al. (2012). Exercise plus volume loading prevents orthostatic intolerance but not reduction in cerebral blood flow velocity after bed rest. Am J Physiol Heart Circ Physiol.
157 Miwa K, Fujita M. (2008). Small heart syndrome in patients with chronic fatigue syndrome. Clin Cardiol.