# Methods

This systematic review follows the methods of the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”31

## Topic Development and Refinement

The initial Key Questions were provided by the Trans-National Institutes of Health (NIH) myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS) Research Working Group and further developed and refined in conjunction with the NIH Pathways to Prevention (P2P) Working Group. AHRQ with input from a Technical Expert Panel (TEP) convened for this report, further developed the approach to the review. The TEP consisted of experts in ME/CFS spanning six disciplines and two patients, who all disclosed no conflicts of interest that precluded participation. The investigators with the Pacific Northwest Evidence-based Practice Center strove to inform themselves of the disease ME/CFS by reviewing Web sites, publications by advocacy groups, and viewing videos of patient experiences. A local infectious disease physician who has treated ME/CFS patients for almost 30 years also participated as a consultant throughout the topic refinement and systematic review process. Two attendees to the International Association for ME/CFS Biennial Conference in San Francisco (March 2014) further informed the team of investigators to the current state of knowledge about the disease and assisted in identifying important outcomes of interest to patients and researchers.

With input from the TEP, the NIH, and AHRQ, the final protocol was developed and posted on the AHRQ Web site on May 1, 2014 at: http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=1906&pageaction=displayproduct[underlined: .] The protocol was also registered in the PROSPERO international database of prospectively registered systematic reviews.32

## Literature Search Strategy

A research librarian conducted searches in Ovid MEDLINE (1988 to September 2014), PsycINFO (1988 to September 2014), the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through September 2014), and the Database of Abstracts of Reviews of Effects and the National Health Sciences Economic Evaluation Database (through the third quarter 2014). See Appendix A for the search strategies. Searches were supplemented with hand searches of reference lists of relevant studies. In addition, scientific information packets were requested from drug and device manufacturers that potentially had data on the use of medications or devices for myalgic encephalomyelitis (ME) or chronic fatigue syndrome (CFS); they had the opportunity to submit data using the portal for submitting scientific information packets on the Effective Health Care Program Web site. Seventeen submissions were received, but provided no research meeting inclusion criteria for this review.

## Process for Study Selection

Criteria for inclusion and exclusion of studies were developed based on the Key Questions and the populations, interventions, comparators, outcomes, timing, types of studies, and setting (PICOTS) approach (Appendix B). Papers were selected for review if they were about diagnosis or treatment of ME or CFS in adult populations, were relevant to a Key Question, and met the prespecified inclusion criteria. Studies of nonhuman subjects and studies with no original data were excluded. Abstracts were reviewed by two investigators for inclusion for each Key Question. Full-text articles were obtained for all studies that either investigator identified as potentially meeting inclusion criteria. Two investigators independently reviewed all full-text articles for final inclusion. Inclusion was restricted to English-language articles. A list of the included studies appears in Appendix C; a list of excluded studies and primary reasons for exclusion can be found in Appendix D. Discrepancies were resolved through discussion and consensus, with a third investigator making the final decision if necessary.

### Population and Conditions of Interest

For Key Question 1, studies of adults 18 years or older with a symptoms in which ME/CFS was a diagnostic consideration were included. For Key Question 2, studies of adults 18 years or older, diagnosed with ME, CFS, or both by fulfilling criteria from at least one of the case definitions and without another underlying diagnosis were included. Studies varied in how they described which case definition they used; for consistency in this report we have used the names identified in Table 1 have been used throughout the report. To minimize heterogeneity in patient populations, we did not include studies in which patients who may have met criteria for ME/CFS were included as part of a broader grouping of an overlapping condition (i.e., depression, fibromyalgia) were not included.

### Interventions, Comparisons, and Study Designs

For Key Question 1, any diagnostic test or case definition (set of clinical criteria) for diagnosing ME/CFS was included. Because there is no single accepted definition for ME/CFS and therefore no “gold standard,” any of the eight case definitions published since 1988 was accepted as a reference standard and compared for similarities and differences. Measures of diagnostic accuracy and concordance were considered. Diagnostic accuracy is a measure of how well the test can distinguish those who do and do not have the disease of interest and is measured by the model’s concordance statistic or c-stat. The c-stat is determined by the area under the receiver operator curve (AUROC) which is a measure of discrimination, the ability of a test to distinguish people with a condition from people without the condition, and is based on the sensitivity and specificity of the test.33,34 An AUROC of 1.0 indicates perfect discrimination, and an AUROC of 0.5 indicates complete lack of discrimination and would result from chance alone. Interpretation of AUROC values between 0.5 and 1.0 is somewhat arbitrary, but a value of 0.90 to 1.0 has been classified as excellent, 0.80 to less than 0.90 as good, 0.70 to less than 0.80 as fair, and less than 0.70 as poor.35 Concordance refers to how well two tests agree. We excluded studies designed to inform etiology and studies that reported on diagnosing a specific symptom of ME/CFS (e.g., post-exertional malaise36) without reporting on diagnosis of ME/CFS by comparing with a case definition as a reference standard. In the absence of studies reporting accuracy/concordance measures, descriptive studies comparing diagnostic clinical criteria were included. For harms of diagnosis, studies that evaluated harms by surveys, qualitative interviews, or trials designed to identify perceptions of diagnosis or treatment for ME/CFS were included.

For Key Question 2, we included randomized trials comparing medication management (immune modulators, beta blockers, antidepressants, anxiolytics, stimulants, other), complementary and alternative medicine (CAM) approaches (acupuncture, relaxation, massage, other), counseling and behavior therapy, and exercise therapies with placebo, no treatment, usual care, or other active interventions, including combination therapies and head-to-head trials. For harms, cohort studies with control groups were also included.

### Outcomes

For Key Question 1, outcomes of diagnostic accuracy or concordance were considered, including sensitivity, specificity, positive predictive value, negative predictive value, positive likelihood ratio, negative likelihood ratio, C-statistic, receiver operator curve (ROC) and area under curve (AUC), net reclassification index, concordance, and any potential benefit or harm from diagnosis (i.e., psychological harms, labeling, risk from diagnostic test, misdiagnosis).

For Key Question 2, outcomes were included if they were patient-centered and included patient reported measures considered clinically relevant, such as function (e.g., 36-item Short Form Survey [SF-36]), quality of life, days spent at work or school, proportion working full- or part-time, and fatigue (Multidimensional Fatigue Inventory 20-item [MFI-20] or similar). Fatigue was included as it was the only symptom that was universal to all case definitions. Other individual symptom-based outcomes (e.g., pain, sleep, memory, PEM) and intermediate outcomes (e.g., biomarker values) were excluded. Harms included, but were not limited to withdrawals, withdrawals due to harms, and rates of harms due to interventions.

### Timing

There was no duration or timing restriction on studies included for Key Question 1. For Key Question 2, only studies with a minimum duration of 12 weeks of treatment were included, given the fluctuating nature of the condition characterized by an intermittent pattern of relapse and remission.37

### Setting

Studies for all Key Questions had to be conducted in a clinical setting or a setting that was generalizable to clinical practice settings. Studies conducted with inpatients or institutionalized individuals were excluded.

## Data Extraction and Data Management

The following information was extracted from included studies into evidence tables: study design, setting, inclusion and exclusion criteria, population characteristics (including sex, age, race, and co-morbidities), sample size, duration of followup, attrition, intervention characteristics, case definition used for diagnosis, duration of illness, and results. Data extraction for each study was performed by two investigators: the first investigator extracted the data, and the second investigator independently reviewed the extracted data for accuracy and completeness.

## Individual Study Quality Assessment

The quality (risk of bias) of each study was assessed based on predefined criteria adapted from methods proposed by the U.S. Preventive Services Task Force. The criteria used are consistent with the approach recommended by AHRQ in the AHRQ Methods Guide.31 The term “quality” was used rather than the alternate term “risk of bias;” both refer to internal validity. Two investigators independently assessed the quality of each study. Discrepancies were resolved through discussion and consensus, with a third investigator making the final decision if necessary.

To determine the quality of each study evaluating diagnostic tests, we used questions from the AHRQ “Methods Guide for Medical Test Reviews”38 were adapted to improve their clinical relevance to ME/CFS. Quality was based on whether the study evaluated a representative spectrum of patients, including patients with overlapping conditions and those with diagnostic uncertainty; whether it enrolled a random or consecutive sample of patients meeting prespecified criteria; whether it used a credible reference standard; whether the same reference standard was applied to all patients; whether the reference standard was interpreted independently from the test under evaluation; and whether thresholds were prespecified.31,39,40 Given the lack of a universally accepted reference standard for ME/CFS, use of more broadly accepted research and clinical criteria were accepted as a comparator (CDC, Canadian, and International definitions). Descriptive papers that compared diagnostic criteria and reported harms were not quality rated.

The quality of intervention trials was based on the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; adequate reporting of dropouts, attrition, crossover, adherence, and contamination; loss to followup; the use of intent-to-treat analysis; and ascertainment of outcomes.31,40

Following assessment of individual quality criteria, individual studies were rated as “good,” “fair,” or “poor” quality, as defined below.31,38

Good-quality studies are considered likely to be valid. Good-quality studies clearly describe the population, setting, interventions, and comparison groups; use a valid method for allocation of patients to interventions; clearly report dropouts and have low dropout rates; use appropriate methods for preventing bias; assess outcomes blinded to intervention status; and appropriately measure outcomes and fully report results.

Fair-quality studies have some methodological deficiencies, but no flaw or combination of flaws judged likely to cause major bias. The study may be missing information, making it difficult to assess its methods or assess limitations and potential problems. The fair-quality category is broad, and studies with this rating vary in their strengths and weaknesses: the results of some fair-quality studies are likely to be valid, while others are probably invalid.

Poor-quality studies have significant flaws that may invalidate the results. They have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting. The results of these studies are judged to be at least as likely to reflect flaws in the study design as true effects of the interventions under investigation. Poor-quality studies were not excluded a priori, but they were considered to be the least reliable studies when synthesizing the evidence, particularly when discrepancies between studies were present. For detailed quality assessment criteria see Appendix E.

## Assessing Research Applicability

Applicability is defined as the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under “real-world” conditions.31 It is an indicator of the extent to which research included in a review might be useful for informing clinical decisions in specific situations. Applicability depends on the particular question and the needs of the user of the review. There is no generally accepted universal rating system for applicability. In addition, applicability depends in part on context. Therefore, a rating of applicability (such as “high” or “low”) was not assigned because applicability may differ based on the user of this review. Rather, factors important for understanding the applicability of studies were recorded, such as how similar patients were to the population of interest, how large the sample size was, and the characteristics of the clinical setting.41 The funding source for treatment trials was also recorded.

## Data Synthesis

Results of diagnostic accuracy studies (such as creating summary AUROCs) were not quantitatively pooled due to differences in methods, case definitions, and heterogeneity in the outcomes. Instead, descriptive statistics were used, such as the median sensitivity and specificity at specific cutoffs and reported AUROCs, along with associated ranges, and calculated positive and negative likelihood ratios based on the median sensitivities and specificities. For the results of intervention trials, the appropriateness of meta-analysis was determined by considering the internal validity of the studies and the heterogeneity among studies in design, patient population, interventions, and outcomes. Appropriate measures were chosen based on the type of data for meta-analysis, according to the guidance for the Evidence-based Practice Center Program.42 Random-effects models were used to estimate pooled effects.43 When only two studies were available we chose not to pool the results.43 We calculated pooled RR where the data were reported as proportions of dichotomous outcomes (e.g., proportion with improvement in intervention and control groups). For continuous outcomes, we calculated pooled weighted mean differences using the means and standard deviations (SDs) (e.g., mean change in function based on a scale). The Q statistic and the I-squared statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess heterogeneity in effects between studies.44,45 When statistical heterogeneity was found, we explored the reasons by using subgroup analysis. In meta-analysis, we combined RRs and ORs for such outcomes.

## Grading the Body of Evidence for Each Key Question

The overall strength of evidence was assessed for each Key Question and outcome in accordance with the AHRQ Methods Guide.31,38 Strength of evidence was based on the overall quality of each body of evidence, the study limitations (graded low, moderate, or high); the consistency of results between studies (graded consistent, inconsistent, or consistency unknown when only one study was available); the directness of the evidence linking the intervention and health outcomes (graded direct or indirect); the precision of the estimate of effect, based on the number and size of studies and confidence intervals (CI) for the estimates (graded precise or imprecise); and whether reporting bias was suspected (graded suspected or undetected). There was no way to formally assess for publication bias due to the small number of studies, methodological shortcomings, or differences across studies in designs, measured outcomes, and other factors. For a more detailed description of the categories used see Appendix F. Studies included to answer Key Question 1 were not formally evaluated for strength of evidence, but key concepts of strength of evidence are discussed.

The strength of evidence was rated for Key Question 2 using the four categories recommended in the AHRQ Methods Guide:31,38 A “high” grade indicates high confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies and the findings are stable (i.e., another study would not change the conclusions). A “moderate” grade indicates moderate confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies and findings are likely to be stable, but some doubt remains. A “low” grade indicates low confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both) and additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect. An “insufficient” grade indicates inability to estimate an effect or no confidence in the estimate of effect for this outcome, no evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

## Peer Review and Public Commentary

Experts in ME/CFS, individuals representing important stakeholder groups, and TEP members were invited to provide external peer review of this systematic review. The AHRQ Task Order Officer and a designated Evidence-based Practice Center Associate Editor also provided comments and editorial review. To obtain public comment, the draft report was posted on the AHRQ Web site for 4 weeks in September and October 2014. The draft report was further edited in response to these reviews and comments, and the specific responses were outlined in a table that will be made available after AHRQ posts the final systematic review on the public Web site.