# Introduction

This systematic review was commissioned by the Office of Disease Prevention at the National Institutes of Health (NIH), sponsored by the NIH Office of Research on Women’s Health, and cosponsored by the Trans-NIH Myalgic Encephalomyelitis/Chronic Fatigue Syndrome (ME/CFS) Research Working Group to inform the NIH 2014 Pathways to Prevention Workshop, an evidence-based methodology workshop. The purpose of the workshop is to develop a research agenda. Accordingly, this review evaluates and summarizes research on methods for diagnosis of ME/CFS and the benefits and harms of treatments, and identifies gaps and limitations of current studies and needs for future research in these areas. This systematic review is not intended to form the basis for treatment guidance.

## Background

Myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS) is a multisystem debilitating condition characterized by chronic and disabling fatigue, as well as various additional manifestations, including neurological and cognitive changes, motor impairment, pain, sleep disturbance, and altered immune and autonomic responses.1–4 It follows a relapsing and remitting course that often leads to loss of independence and reduced quality of life.1 Experts consider post-exertional malaise/neuroimmune exhaustion (PEM) and memory or concentration problems as key components.5–7

Although reports of similar symptom clusters date back to the 1930s, the term myalgic encephalomyelitis (ME) was first used to describe the condition in the 1950s and was recognized by the World Health Organization in the 1960s.8 The term chronic fatigue syndrome (CFS) was coined in the 1980s after research failed to identify a clear viral association with what was previously labeled chronic Epstein-Barr virus syndrome.9–12 Other terms such as post viral fatigue syndrome and chronic fatigue immune dysfunction syndrome have been used in an attempt to associate the syndrome with possible underlying etiologies.2,4,9,10 The most recent international consensus report advocates moving away from the term CFS in favor of the term ME to better reflect an underlying disease process involving widespread inflammation and neuropathology.3,7 Some feel that the lack of specificity surrounding the name, CFS, may delegitimize and negatively characterize the condition, and stigmatize patients.13,14 Consistent with the NIH Workshop, this review uses the combined term ME/CFS to describe the condition and includes studies using either ME or CFS criteria.

Uncertainty persists regarding the etiology of ME/CFS, whether it is a pathologically discrete syndrome,3,7 whether ME should be considered a subset of CFS or its own distinct disease,5 or whether the symptom set is nonspecific and shared by other disease entities. Some suggest that an inciting event triggers an immune response and promotes immune and/or neuroendocrine dysregulation that perpetuates the body’s response and symptom experience that becomes ME/CFS.15,16 Viral etiologies have been predominantly studied based on the observation that the majority of patients report a sudden onset of symptoms associated with a preceding febrile illness and enlarged lymph nodes. However, no specific virus or other infectious agent has been identified, and not all patients experience a preceding febrile illness.15 Numerous studies have attempted to identify risk factors for developing ME/CFS. A systematic review in 2008 of 11 studies assessing predictive models of multiple risk factors found no evidence of any definitive factors.17 For example, although some models found association with older age, women, and febrile viral illness, others did not.17 It is known that ME/CFS is more common among women with the average age of diagnosis between 30 and 40 years.18 This review is not intended to address the question of etiology nor underlying factors that lead to the onset or perpetuation of ME/CFS but rather to focus on the diagnosis and treatment of this syndrome.

Diagnosing a patient with ME/CFS relies on the use of a set of clinical criteria (case definitions) to distinguish ME/CFS from other conditions that may also present with fatigue. There are eight published case definitions that have evolved since the first one was published by the Centers for Disease Control and Prevention (CDC) in 1988^10^ (Table 1). All but one of the definitions include persistent fatigue not attributable to a known underlying medical condition, as well as additional clinical signs and symptoms that do not all need to be present to establish the diagnosis.5 The case definitions overlap but vary greatly in their symptom set, leading to concern that they do not all represent the same disease or identify the same cohort of patients.7 The international ME consensus panel of experts recommends that patients meeting the International Consensus Criteria (ICC) be given the name ME, and that those meeting the criteria for CFS but not the ICC for ME be given the name CFS.7 For this report we have considered all case definitions, recognizing that no case definition has been accepted as a reliable reference standard (“gold standard”) and that unresolved issues persist.

Table 1 Case definitions

Symptoms | London ME | Canadian ME/CFS | Revised Canadian ME/CFS | International ME | CDC – CFS Holmes | Oxford CFS | CDC – CFS Fukuda | CDC – CFS Reeves
General physical | X | X | X | | X | X | X | X
Neurological; neurocognitive | X | X | X | X | X | X | X | X
Post exertional malaise | X | X | X | X | X | | X | X
Neuroendocrine; immune | | X | X | X | X | | X | X
Other system involvement | | | | X

Abbreviations: CDC = Centers for Disease Control and Prevention; CFS = chronic fatigue syndrome; ME = myalgic encephalomyelitis.

As with other medical syndromes that involve a multitude of symptoms and lack a definitive diagnostic test, differentiating one disease state from another similar or overlapping condition becomes a challenge. Some clinicians are reluctant to diagnose ME/CFS, believing that the diagnosis will harm the patient or that the patient will be inappropriately labeled.19 This makes the prevalence of ME/CFS difficult to assess.18,20 The CDC reported a U.S prevalence rate of 0.3 percent corresponding to over 1,000,000 adults in 1997.^21^ By using different case definitions, the rate may be as high as 2.5 percent.9,22 A recent systematic review found that when using the same case definition (CDC Fukuda, 1994), the prevalence was higher when determined by self report (3.28%; 95% confidence interval [CI], 2.24 to 4.33) compared with clinical assessment (0.76%; 95% CI, 0.23 to 1.29).23 The prevalence and symptom patterning of childhood ME/CFS is similar but is more likely to develop after an acute flu-like or mononucleosis-like illness, and the prognosis appears to be better.24–26 The natural history of ME/CFS in adults is not well studied, but symptoms and disability in adults tend to persist over time.27 Although 40 percent (8 to 63%) of adult patients improve, only 5 percent (0 to 31%) fully recover,21 in contrast to childhood studies that suggest that over 50 percent of patients will recover within 6 months.25 However, a recent review highlighted the variability in which studies defined recovery in adults, limiting the utility of this term as a meaningful outcome until a universal definition for recovery is accepted.28 The review authors recommended using a more global assessment that captured fatigue, function, and perception of health.28 Regardless, economic impact is considerable with most adult patients never returning to work.15,29

Currently there are no medications for the treatment of ME/CFS approved by the U.S Food and Drug Administration (FDA), but many have been used without review and approval (“off-label”), and some have been obtained from other countries and are not currently approved for any indication in the United States (i.e., isoprinosine, rintatolimod). In an FDA survey, patients identified treatments that fell into two broad categories: those intended to treat the underlying cause of the disease and those targeting specific symptoms or perpetuating factors.30 Medications to treat underlying causes include immune modulators, antivirals, and antibiotics. Interventions targeting symptoms include medications to treat specific symptoms such as pain, fatigue, autonomic dysfunction, and sleep dysfunction, and nondrug therapies such as yoga, exercise techniques, counseling, pacing strategies, and mental exercises.30 In practice, there are wide variations in the clinical management of patients, and many patients receive a multifaceted approach to treatment.

The variable symptomatology of ME/CFS, lack of a clearly identifiable etiology and/or disease process, and lack of an agreed upon reference standard for diagnostic testing have challenged researchers and clinicians in their attempts to better understand the condition and treat patients. This review summarizes the research on diagnosis and treatment of the syndrome, including the methods and criteria used to diagnose ME/CFS, their utility in differentiating patients with similar but distinct symptoms, the harms associated with carrying a diagnosis of ME/CFS, and the evidence on treatment effectiveness and associated harms. Although they are recognized as important components in advancing the research and understanding of ME/CFS, this review does not address theories surrounding etiology/pathophysiology nor intermediate outcomes of treatment, such as changes in biomarker values, as these topics will be addressed by other presenters at the workshop. This review identifies limitations and gaps in the current state of the literature and how the existing research applies to patients in order to assist the P2P panel in their recommendations regarding future research.

## Scope of Review and Key Questions

The research questions were developed by the P2P Working Group, that included experts and a patient advocate, and they focus on diagnosis and treatment of the syndrome ME/CFS. The analytic framework (Figure 1) and Key Questions used to guide this review are shown below. The analytic framework shows the target populations, interventions, and health outcomes examined, with numbers corresponding to the Key Questions.

Figure 1 Analytic framework

Figure 1 is an analytic framework that depicts the events involved in the diagnosis and treatment of symptomatic adults for myalgic encephalomyelitis (ME) and/or chronic fatigue syndrome (CFS). The figure shows that adults with a symptom complex in which ME/CFS is a diagnostic consideration undergoing diagnosis may lead to a diagnosis of ME and/or CFS or to a diagnosis of another condition. Diagnosis may potentially cause harms. The figure then indicates that after diagnosis with ME and/or CFS patients may undergo treatment, which may lead to intermediate outcomes, then to improved overall function, improved quality of life, more days spent at work or school, proportion working full- or part-time, and decreased fatigue. Treatment may also result in harms. The figure, including key questions, and populations, interventions, comparators, outcomes, and settings of interest are described further in the report.

The report focuses on the following Key Questions:

Key Question 1 What methods are available to clinicians to diagnose ME/CFS, and what conditions are required to be ruled out or excluded before assigning a diagnosis of ME/CFS?
  Key Question 1a What are the accuracy and concordance of methods used to diagnose ME/CFS?
  Key Question 1b How does the use of these methods vary by patient subgroups?
  Key Question 1c What harms are associated with diagnosing ME/CFS?
Key Question 2 What are the (a) benefits and (b) harms of therapeutic interventions for patients with ME/CFS. and how do they vary by patient subgroups?
  Key Question 2c What are the characteristics of responders and nonresponders to interventions?