# Peer Reviewers

Prior to publication of the final evidence report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Todd Davenport, D.P.T., O.C.S.
  Associate Professor, Department of Physical Therapy
  University of the Pacific
  Stockton, CA
- Derek Enlander, M.D.
  Clinician, Mount Sinai School of Medicine; Attending Physician, Mount Sinai Medical Center
  New York, NY
  Director: New York ME/CFS Center
- Maureen Hanson, Ph.D.
  Liberty Hyde Bailey Professor, Department of Molecular Biology and Genetics
  Cornell University
  Ithaca, NY
- Alan R. Light, Ph.D.
  Research Professor, Department of Anesthesiology
  Adjunct Professor, Department of Neurobiology and Anatomy
  University of Utah School of Medicine
  Salt Lake City, UT
- Rosemary Underhill, M.B.B.S., FRCS(E)
  Independent Researcher
  Palm Coast, FL
  Consultant: New Jersey ME/CFS Association