# Technical Expert Panel

In considering the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Gordon Broderik, Ph.D.
  Professor, Center for Psychological Studies
  Director, Clinical Systems Biology Lab
  Institute for Neuro Immune Medicine, Nova
  Southeastern University
  Fort Lauderdale, FL
- Fred Friedberg, Ph.D.
  Research Associate Professor
  Stony Brook School of Medicine
  Stony Brook, NY
  Founder and Editor: Fatigue: Biomedicine, Health and Behavior
  President: International Association for Chronic Fatigue Syndrome/Myalgic Encephalomelitis
- Miles Hassel, M.D.
  Medical Director, Providence Integrative
  Medicine Program
  Providence Cancer Center
  Portland, OR
- Anthony L. Komaroff, M.D.
  Steven P. Simcox, Patrick A. Clifford and James H. Higby Professor of Medicine
  Brigham and Women’s Hospitals
  Harvard Medical School
  Boston, MA
  Editor in Chief: Harvard Health Publications
  Board Member: International Association for Chronic Fatigue Syndrome/Myalgic Encephalomyelitis
- Christopher Snell, Ph.D.
  Professor Emeritus, Health, Exercise and Sport Sciences Department
  University of the Pacific
  Stockton, CA
  Chair: Scientific Advisory Committee, Workwell Foundation
- Staci R Stevens, M.A.
  Ripon, CA
  Founder: Workwell Foundation
  Vice President: International Association for Chronic Fatigue Syndrome/Myalgic Encephalomyelitis

Two patient advocates were also members of the Technical Expert Panel.