# Key Informants

This topic was nominated to AHRQ by NIH. Therefore, in place of Key Informants, an NIH Working Group Planning Meeting was conducted to design the Key Questions and the scope of the report.