# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Richard Bryant, M.D., for providing expert consultation throughout the report, Andrew Hamilton, M.L.S., M.S., for conducting literature searches, and Spencer Dandy, B.S., for assistance with preparing this report (all are located at the Oregon Health & Science University); Suchitra Iyer, Ph.D., Task Order Officer at the Agency for Healthcare Research and Quality; Carmen Green, M.D., National Institutes of Health (NIH) Working Group Chair; and the NIH Working Group.