# Appendix K Strength of Evidence

Table K1 Strength of evidence