# Appendix J Standardized Measures Tables

Table J1 Standardized measures used in evaluation of case definitions of ME/CFS

Measure | Abbreviation | Description | Validation studies in ME/CFS population
Beck Depression Inventory1 | BDI | Self-reported multiple-choice inventory of 21-questions for measuring the severity of depression. Scores of 0–9 indicate minimal depression, 10–18 mild depression, 19–29 moderate depression, 30–63 severe depression. | Validated in population receiving treatment for CFS2
Brief Coping Orientation to Problems Experienced Scale3 | bCOPE | 28 questions that cover 14 coping strategies as potential responses to stressors: self-distraction, active coping, denial, substance use, use of emotional support, use of instrumental support, behavioral disengagement, venting, positive reframing, planning, humor, acceptance, religion, and self-blame. Each item scored on 1–4 scale (1=haven’t been doing this at all and 4=have been doing this a lot), each coping strategy is scored 2–8. | None
Chronic Fatigue Syndrome Medical Questionnaire4 | | Single item of questionnaire: rate the severity of your post-exertional malaise over the past 6 months using scale of 0–100, with lower scores indicating less severity. | Developed for CFS population
Chronic Fatigue Symptoms Checklist5,6 | CFSC | Self-reported set of 40 symptoms, 30 thought to be typical of CFS symptoms and 10 considered atypical. Each item is scored 0–4, with 0=never suffer from it; 1=mild or rare symptoms during the last month causing minor disruption; 2=moderate or frequent symptoms during the last month causing major disruption; 3=severe or very frequent symptoms during the last month unable to perform usual activities; and 4=suffered from it previously for ≥1 month but not now. | Designed for CFS patients
Cognitive Failures Questionnaire7 | CFQ | The CFQ measure self-reported failures in perception, memory and motor function over the previous 6-months. It consists of 25 items, each graded on a scale of 5 point Likert-scale, total scores are calculated by adding the individual item scores. Final scores range from 0–100, lower scores indicate better health. | None
Fatigue Impact Scale8 | FIS | Self- reported instrument of fatigue impact on 40-items subdivided into 3 subscales, cognitive functioning (10-items), physical functioning (10-items), and psychosocial functioning (20-items). Each item is rated from 0 (no problem) to 4 (extreme problem), with a maximum score of 160. | Validated in population who had experienced ≥6 months of fatigue8
General Health Questionnaire9 | GHQ | A 60-item questionnaire to screen individuals for psychiatric disorders, scores are given as means and scores above 3 indicate disorders; a 30-item version of the same questionnaire uses a threshold of 6 to indicate general psychological distress. | None
Hospital Anxiety and Depression Scale10 | HADS | Self-reported scale of 14-items for the detection of depression and anxiety in hospitalized patients. Scores range from 1–21 interpreted as: normal (0–7), mild (8–10), moderate (11–14), severe (15–21). Subscales for anxiety (HADS-A) and depression (HADS-D). | Validated in patients identified using CDC (Fukuda, 1994) criteria11
Karnofsky Performance Scale12 | KPS | Descriptive ordinal scale that measures the patient’s ability to carry on normal activities/the degree of assistance required. The scale range is comprised of 10-point intervals from 0–100, where 0=dead and 100=normal, no complaints or evidence of disease. Score thresholds: 80–100=normal health; 50–80=an inability to work, with a varying amount of assistance needed at home; 10–40=an inability for self care requiring the equivalence of institutional care | Validated in patients with chronic pain, but not specifically CFS13
Multidimensional Fatigue Inventory14 | MFI-20 | Self-reported instrument used to measure fatigue consisting of 5 subscales: general fatigue, physical fatigue, mental fatigue, reduced motivation, and reduced activity. Each subscale has 4 statements regarding levels of fatigue experienced in the previous days (20 total) rated on a Likert-type scale from 1–5 for a final subscale score of 4–20, lower scores indicate less fatigue. | Validated in those with >12 months of fatigue14 Validated in population self-reporting symptoms meeting CDC (Fukuda, 1994) criteria15
Modified Somatic Perception Questionnaire16 | MSPQ | Self-reported 13-item scale for patients with chronic pain or disabilities, it is used to identify somatic complaints that may be associated with psychological responses such as anxiety or depression. Each item is scored 0–3 (0=not at all and 3=extremely could not have been worse) for a total score of 0–39 with lower scores indicated lower general somatic symptoms. | None
Orthostatic Grading Scale17 | OGS | Self-reported 5-item scale assessing for symptoms of orthostatic intolerance because of orthostatic hypotension. Each item is scored 0–4, with total score of 0–20, with lower scores indicated better health. | None
Pennebaker Inventory of Limbic Languidness18 | PILL | Self-reported 54-item questionnaire measures the tendency for someone to notice and report a broad array of physical symptoms and sensations. Each item scored from 0–4 (0=never or almost never experienced and 4=more than once a week) for a total score of 0–216 interpreted as: 0–21 below normal range; 22–66 well within normal range; 67–84slighly above average, within normal range; and ≥85 top 25%. | None
Sickness Impact Profile 8-items19,20 | SIP-8 | Self-reported measure of perceived impact of illness or disease on physical and psychosocial functioning, it can be self or interviewer administered. The 8 subscales used are home management, mobility, alertness behavior, sleep/rest, ambulation, social interactions, work and recreation and pastimes. A total score is calculated by addition of the weights of items (range 0–5,799). Lower scores indicate better health. | None
36-item Short Form survey21 | SF-36 | Self-reported survey of 36 questions of patient health on 8 subscales: vitality, physical functioning, bodily pain, general health perceptions, physical role functioning, emotional role functioning, social role functioning, and mental health. The scale has a range from 0–100, with higher scores indicating better health. | Validated in those identified using CDC (Holmes, 1988) criteria22,23
Somatization Checklist 24 | None | Self-reported set of 39 physical symptoms derived from diagnostic interview schedule for making a DSM-III/III-R diagnosis of somatization disorder. Items were answered yes or no for current and lifetime symptoms. | None
Symptom Checklist-90^25^ | SCL-90 | Self-reported checklist of 90 questions to assess psychological status in the following categories: somatization, obsessive-compulsive, interpersonal sensitivity, depression, anxiety, hostility, phobic anxiety, paranoid ideation, psychoticism. | None
Zung Self-Rating Depression Scale26 | ZDS | Self-reported questionnaire of 20-items that rate affective, psychological, and somatic symptoms associated with depression. Each item is rated from 1 (a little of the time) to 4 (most of the time) with final scores ranging from 20–80, interpreted as: 20–44 normal, 45–59 mildly depressed, 60–69 moderately depressed, ≥70 severely depressed. | None

Abbreviations: BDI = Beck Depression Inventory; bCOPE = brief Coping Orientation to Problems Experienced scale; CDC = Centers for Disease Control and Prevention; CFS = Chronic Fatigue Syndrome; CFSC = chronic fatigue symptoms checklist; CFQ= Cognitive Failures Questionnaire; DSM III/III-R= Diagnostic and Statistical Manual third edition/third edition revised; GHQ = General Health Questionnaire; HADS = Hospital Anxiety and Depression Scale; HADS-A = anxiety subscale of HADS; HADS-D = depression subscale of HADS; KPS = Karnofsky Performance Scale; MFI-20 = Multidimensional Fatigue Inventory 20-Item; MSPQ = Modified Somatic Perception Questionnaire; PILL= Pennebaker Inventory of Limbic Languidness; SIP-8 = Sickness Impact Profile 8-Item; SF-36 = Short Form-36; SCL-90 = Symptom Checklist; ZDS = Zung Self-Rating Depression Scale.

Table J2 Standardized measures used to assess outcomes after interventions for ME/CFS

Measure | Abbreviation | Description | Validation studies in ME/CFS population
Abbreviated Fatigue Questionnaire27 | SFQ | Self-reported measure of fatigue consisting of 4 questions answered on a 7-point Likert-type scale. Final scores range from 4–28, with higher scores indicate lower levels of fatigue. | None
Clinical global impression change score28 | CGI | Clinician-rated clinical global impression of change. Levels of improvement after intervention is rated on a 7 point Likert-type scale where 1=very much better and 7=very much worse. Note: Several studies had the patients self-report their ratings instead of a clinician. | None
Chalder Fatigue Scale29 | None | Self-reported, 14- or 11-item fatigue scale. Items scored dichotomously on a 4-point scale (0,0,1,1), lower scores indicate better outcomes, total scores ≥4 designate clinically significant levels of fatigue. Note: Several different scoring methods are used for this scale. | Validated in those identified using Oxford (Sharpe, 1991) criteria30 Validated in CFS patient meeting either Oxford (Sharpe, 1991) or CDC (Fukuda, 1994) criteria31
Checklist of Individual Strength19 | CIS | Self-reported questionnaire measuring several aspects of fatigue, 20-items, separated into 4 subscales: severity of fatigue (8-items), concentration problems (5-items), decrease motivation (4-items), and decreased physical activity (3-items). Each item is rated on a 7-point Likert-type scale for final scores of 20–140. Lower scores indicate better health. | Validated in patients with >1 year self-reported fatigue unexplained by other diagnosis19
EuroQol Scale32 | None | Measures health status, with scores ranging from 0=worst health status to 100=best health status. | Validated in population meeting Oxford (Sharpe, 1991) criteria33
Fatigue Impact Scale8 | FIS | Self- reported instrument of fatigue impact on 40-items subdivided into 3 subscales, cognitive functioning (10-items), physical functioning (10-items, and psychosocial functioning (20-items). Each item is rated from 0 (no problem) to 4 (extreme problem), with a maximum score of 160. | Validated in population who had experienced ≥6 months of fatigue8
Fatigue Severity Scale34 | FSS | Self-reported measure of fatigue, composed of 9-items rated on 7-point Likert-type scales, where 1=no fatigue-related impairment and 7=high impairment. Final scores range from 9–63, lowers scores indicate lower fatigue impairment. | Validated in patients with CFS like symptoms, but not formally diagnosed35
Fibromyalgia Impact Questionnaire36 | FIQ | Self-reported 10-item measure that assesses the current health status of patients with fibromyalgia on physical functioning, work status, depression, anxiety, sleep, pain, stiffness, fatigue, and wellbeing. Each item has multiple questions scored on Likert-type scales, for a final score ranging from 0–100. Lower scores indicate better health. | None
Karnofsky Performance Scale12 | KPS | Descriptive ordinal scale that measures the patient’s ability to carry on normal actives/the degree of assistance required. The scale range is comprised of 10-point intervals from 0–100, where 0=dead and 100=normal, no complaints or evidence of disease. Score thresholds: 80–100=normal health; 50–80=an inability to work, with a varying amount of assistance needed at home; 10–40=an inability for self care requiring the equivalence of institutional care | Validated in patients with chronic pain, but not specifically CFS13
Medical Outcome Study Short Form37 | MOS-SF | Measures functioning and well being of 6 health concepts: physical functioning, social functioning role functioning, mental health, health perceptions, and bodily pain. Each area has varying numbers of items and are scored on scales from 1–100, with higher scores indicating better health. | Validated in patients with chronic conditions38 Validated in those identified using Oxford (Sharpe, 1991) criteria39
Modified barthel’s Activities of Daily Living index40 | ADL | Self-reported measure that measures the patient’s ability to preform 83 discrete activities of daily living. The maximum score is 100, higher scores indicate better health. | None
Multidimensional Fatigue Inventory14 | MFI-20 | Self-reported instrument used to measure fatigue consisting of 5 subscales: general fatigue, physical fatigue, mental fatigue, reduced motivation, and reduced activity. Each subscale has 4 statements regarding levels of fatigue experienced in the previous days (20 total) rated on a Likert-type scale from 1–5 for a final subscale score of 4–20, lower scores indicate less fatigue. | Validated in those with >12 months of fatigue14 Validated in population self-reporting symptoms meeting CDC (Fukuda, 2004) criteria15
Profile of Mood States41 | POMS | Self-reported scale used to assess transient mood states, consisting of 65 adjectives, separated into 6 subscales: tension-anxiety, depression-dejection, anger-hostility, fatigue, vigor, confusion. Each item is rated on a 5-point Likert-type scale, items for the subscales are combined with vigor scores subtracted for an overall score ranging from 0–200. For this review, only the fatigue and vigor subscales were included. The maximum score for the fatigue subscale is 28, and the maximum score for the vigor subscale is 32. | None
Quality of Life Index42,43 | QLI | Self-reported questionnaire covering 34-items related to quality of life overall and in 4 subscales: health and functioning, social and economic, psychological/spiritual, and family. The first part of the questionnaire rates satisfaction with 34-items on a 6-point Likert-type scale ranging from very dissatisfied to very satisfied (−2.5 to 2.5 for analysis). The second part of the questionnaire rates the importance of these items from 1=very unimportant to 6=very important. Final scores for each subscales and the total scale range from 0–30 and are computed by weighting satisfaction responses with paired importance responses. Higher scores indicate higher life quality. | Used in CFS populations, but unclear if validated44
Quality of Life Inventory45,46 | QOLI | Inventory of patient satisfaction and happiness in 17 (16 in the more recent version) areas of life potentially relevant to overall life satisfaction. Each area is first rated in terms of importance to overall happiness where 0=not at all important, 1=important, and 2=very important. The items are then rated in terms of the patient satisfaction with that area on a scale ranging from −3 (very dissatisfied) to 3 (very satisfied). The 2 scores are multiplied to produce weighted satisfaction ratings ranging from −6 to 6 and the overall life satisfaction score is obtained by averaging all weighted satisfaction ratings that have nonzero importance ratings. Higher scores indicate better health. | None
Quality of Life Scale47 | QLS | 16-items answered on a 7-point Likert-type scale which measures 6 conceptual domains of quality of life: material and physical well-being; relationships with other people; social, community and civic activities; personal development and fulfillment; recreation; and independence. Scored on a 16–113 scale, higher scores indicate better quality of life. | None
36-item Short Form Survey 21 | SF-36 | Self-reported survey of 36 questions of patient health on 8 subscales: vitality, physical functioning, bodily pain, general health perceptions, physical role functioning, emotional role functioning, social role functioning, and mental health. The scale has a range from 0–100, with higher scores indicating better health. For this review, only the physical functioning and vitality subscales were included. | Validated in those identified using CDC (Holmes, 1988) criteria22,23
Short Form 12-Item Health Survey48 | SF-12 | A health survey with 12-items assessing physical and mental health. The survey yields 2 summary scores: the mental component summary and the physical component summary. Each summary score ranges from 0–100, higher scores indicate better health. | None
Sickness Impact Profile 8-items19,20 | SIP-8 | Self-reported measure of perceived impact of illness or disease on physical and psychosocial functioning, it can be self or interviewer administered. The 8 subscales used are home management, mobility, alertness behavior, sleep/rest, ambulation, social interactions, work and recreation and pastimes. A total score is calculated by addition of the weights of items (range 0–5,799). Lower scores indicate better health. | None
Work and social adjustment scale49 | None | A 5-item questionnaire that measures impairment in in work, home management, social activities, and private leisure. Each item is measured on a 0–8 Likert-type scale where 8=maximum impairment. The scale is scored from 0–45. | Validated in CFS populations receiving treatment50

Abbreviations: ADL = Activities of Daily Living; CDC= Centers for Disease Control and Prevention; CFS= chronic fatigue syndrome; CGI= Clinical Global Impression Change Score; CIS= Checklist of Individual Strength; FIQ= Fibromyalgia Impact Questionnaire; FIS= Fatigue Impact Scale; FSS= Fatigue Severity Scale; KPS = Karnofsky Performance Scale; MFI-20=Multidimensional Fatigue Inventory; POMS= Profile of Mood States; QLI= Quality of Life Index; QLS= Quality of Life Scale; QOLI= Quality of Live Inventory; SF-36= Short Form-36; SF-12= Short-Form 12-Item Survey; SFQ= Abbreviated Fatigue Questionnaire; SIP-8= Sickness Impact Profile 8 items.

## References for Appendix J

1 Beck AT, Steer RA, Carbin MG. (1988). Psychometric properties of the Beck Depression Inventory: Twenty-five years of evaluation. Clin Psychol Rev.
2 Brown M, Kaplan C, Jason L. (2012). Factor analysis of the Beck Depression Inventory-II with patients with chronic fatigue syndrome. J Health Psychol.
3 Carver CS. (1997). You want to measure coping but your protocol’too long: Consider the brief cope. Int J Behav Med.
4 Hawk C, Jason LA, Torres-Harding S. (2007). Reliability of a chronic fatigue syndrome questionnaire. J Chronic Fatigue Syndr.
5 Hickie I, Lloyd A, Hadzi-Pavlovic D, et al. (1995). Can the chronic fatigue syndrome be defined by distinct clinical features?. Psychol Med.
6 Hickie I, Lloyd A, Wakefield D, et al. (1990). The psychiatric status of patients with the chronic fatigue syndrome. Br J Psychiatry.
7 Broadbent DE, Cooper PF, FitzGerald P, et al. (1982). The Cognitive Failures Questionnaire (CFQ) and its correlates. Br J Clin Psychol.
8 Fisk JD, Ritvo PG, Ross L, et al. (1994). Measuring the functional impact of fatigue: initial validation of the fatigue impact scale. Clin Infect Dis.
9 Jackson C. (2007). The general health questionnaire. Occup Med.
10 Bjelland I, Dahl AA, Haug TT, et al. (2002). The validity of the Hospital Anxiety and Depression Scale. An updated literature review. J Psychosom Res.
11 McCue P, Buchanan T, Martin CR. (2006). Screening for psychological distress using internet administration of the Hospital Anxiety and Depression Scale (HADS) in individuals with chronic fatigue syndrome. Br J Clin Psychol.
12 Karnofsky DA, Abelmann WH, Craver LF, et al. (1948). The use of the nitrogen mustards in the palliative treatment of carcinoma. With particular reference to bronchogenic carcinoma. Cancer.
13 Grieco A, Long CJ. (1984). Investigation of the Karnofsky Performance Status as a measure of quality of life. Health Psychol.
14 Smets EM, Garssen B, Bonke B, et al. (1995). The Multidimensional Fatigue Inventory (MFI) psychometric qualities of an instrument to assess fatigue. J Psychosom Res.
15 Lin JM, Brimmer DJ, Maloney EM, et al. (2009). Further validation of the Multidimensional Fatigue Inventory in a US adult population sample. Popul Health Metr.
16 Main CJ. (1983). The Modified Somatic Perception Questionnaire (MSPQ). J Psychosom Res.
17 Schrezenmaier C, Gehrking JA, Hines SM, et al. (2005). Evaluation of orthostatic hypotension: relationship of a new self-report instrument to laboratory-based measures. Mayo Clin Proc.
18 Pennebaker JW. (1982). The psychology of physical symptoms.
19 Vercoulen JH, Swanink CM, Fennis JF, et al. (1994). Dimensional assessment of chronic fatigue syndrome. J Psychosom Res.
20 Bergner M, Bobbitt RA, Carter WB, et al. (1981). The Sickness Impact Profile: development and final revision of a health status measure. Med Care.
21 Ware JE, Sherbourne CD. (1992). The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care.
22 Buchwald D, Pearlman T, Umali J, et al. (1996). Functional status in patients with chronic fatigue syndrome, other fatiguing illnesses, and healthy individuals. Am J Med.
23 Komaroff AL, Fagioli LR, Doolittle TH, et al. (1996). Health status in patients with chronic fatigue syndrome and in general population and disease comparison groups. Am J Med.
24 Hadzi-Pavlovic D, Hickie IB, Wilson AJ, et al. (2000). Screening for prolonged fatigue syndromes: validation of the SOFA scale. Soc Psychiatry Psychiatr Epidemiol.
25 Schmitz N, Hartkamp N, Kiuse J, et al. (2000). The Symptom Check-List-90-R (SCL-90-R): a German validation study. Qual Life Res.
26 Zung WW. (1965). A Self-Rating Depression Scale. Arch Gen Psychiatry.
27 Alberts M, Smets EM, Vercoulen JH, et al. (1997). Ned Tijdschr Geneeskd.
28 Guy W. (1976). ECDEU assessment manual for psychopharmacology.
29 Chalder T, Berelowitz G, Pawlikowska T, et al. (1993). Development of a fatigue scale. J Psychosom Res.
30 Morriss RK, Wearden AJ, Mullis R. (1998). Exploring the validity of the Chalder Fatigue scale in chronic fatigue syndrome. J Psychosom Res.
31 Cella M, Chalder T. (2010). Measuring fatigue in clinical and community settings. J Psychosom Res.
32 EuroQol Group. (1990). EuroQol--a new facility for the measurement of health-related quality of life. Health Policy.
33 Myers C, Wilks D. (1999). Comparison of Euroqol EQ-5D and SF-36 in patients with chronic fatigue syndrome. Qual Life Res.
34 Krupp LB, LaRocca NG, Muir-Nash J, et al. (1989). The fatigue severity scale. Application to patients with multiple sclerosis and systemic lupus erythematosus. Arch Neurol.
35 Taylor RR, Jason LA, Torres A. (2000). Fatigue rating scales: an empirical comparison. Psychol Med.
36 Burckhardt CS, Clark SR, Bennett RM. (1991). The fibromyalgia impact questionnaire: development and validation. J Rheumatol.
37 Stewart AL, Hays RD, Ware JE. (1988). The MOS short-form general health survey. Reliability and validity in a patient population. Med Care.
38 Stewart AL, Greenfield S, Hays RD, et al. (1989). Functional status and well-being of patients with chronic conditions. Results from the Medical Outcomes Study. JAMA.
39 Morriss RK, Wearden AJ. (1998). Screening instruments for psychiatric morbidity in chronic fatigue syndrome. J R Soc Med.
40 Mahoney FI, Barthel DW. (1965). Functional Evaluation: The Barthel Index. Md State Med J.
41 McNair, Lorr, Droppelman. (1971). Manual: Profile of Mood States.
42 Ferrans CE, Powers MJ. (1992). Psychometric assessment of the Quality of Life Index. Res Nurs Health.
43 Ferrans CE, Powers MJ. (1985). Quality of life index: development and psychometric properties. ANS Adv Nurs Sci.
44 Anderson JS, Ferrans CE. (1997). The quality of life of persons with chronic fatigue syndrome. J Nerv Ment Dis.
45 Frisch MB, Cornell J, Villanueva M, et al. (1992). Clinical Validation of the Quality of Life Inventory: A Measure of Life Satisfaction for Use in Treatment Planning and Outcome Assessment. Psychological Assessment.
46 Frisch MB. (1994). QOLI: Quality of Life Inventory: Manual and Treatment Guide.
47 Burckhardt CS, Anderson KL. (2003). The Quality of Life Scale (QOLS): reliability, validity, and utilization. Health Qual Life Outcomes.
48 Ware J, Kosinski M, Keller SD. (1996). A 12-Item Short-Form Health Survey: construction of scales and preliminary tests of reliability and validity. Med Care.
49 Mundt JC, Marks IM, Shear MK, et al. (2002). The Work and Social Adjustment Scale: a simple measure of impairment in functioning. Br J Psychiatry.
50 Cella M, Sharpe M, Chalder T. (2011). Measuring disability in patients with chronic fatigue syndrome: reliability and validity of the Work and Social Adjustment Scale. J Psychosom Res.