# Appendix I Published Case Definition Criteria

Table I1 Published case definition criteria