# Appendix H Quality Assessment Tables

Table H1 Quality assessment table of diagnostic accuracy/concordance studies

Table H2 Quality assessment of randomized controlled trials