# Appendix G Data Abstraction Tables

Table G1 Evidence table of included studies evaluating the accuracy and/or concordance of different diagnostic criteria

Table G2 Evidence table of included studies of methods used to diagnose ME/CFS

Table G3 Evidence table of included studies of harms of diagnosis

Table G4 Evidence table of included trials of interventions for ME/CFS