# Appendix F Strength of Evidence Criteria^1^

Table F1 Required domains and their definitions

Domain | Definition and Elements | Score and Application
Study Limitations | Study limitations is the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design: Whether RCTs or other designs such as nonexperimental or observational studies.; - Study conduct. Aggregation of ratings of risk of bias of the individual studies under consideration. | Score as one of three levels, separately by type of study design:; - Low level of study limitations; - Medium level of study limitations; - High level of study limitations
Directness | Directness relates to (a) whether evidence links interventions directly to a health outcome of specific importance for the review, and (b) for comparative studies, whether the comparisons are based on head-to-head studies. The EPC should specify the comparison and outcome for which the SOE grade applies. Evidence may be indirect in several situations such as:; - The outcome being graded is considered intermediate (such as laboratory tests) in a review that is focused on clinical health outcomes (such as morbidity, mortality).; - Data do not come from head-to-head comparisons but rather from two or more bodies of evidence to compare interventions A and B—e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not direct comparisons of A vs. B.; - Data are available only for proxy respondents (e.g., obtained from family members or nurses) instead of directly from patients for situations in which patients are capable of self-reporting and self-report is more reliable.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcome. | Score as one of two levels:; - Direct; - Indirect; If the domain score is indirect, EPCs should specify what type of indirectness accounts for the rating.
Consistency | Consistency is the degree to which included studies find either the same direction or similar magnitude of effect. EPCs can assess this through two main elements:; - Direction of effect: Effect sizes have the same sign (that is, are on the same side of no effect or a minimally important difference [MID]); - Magnitude of effect: The range of effect sizes is similar. EPCs may consider the overlap of CIs when making this evaluation.; The importance of direction vs. magnitude of effect will depend on the key question and EPC judgments. | Score as one of three levels:; - Consistent; - Inconsistent; - Unknown (e.g., single study); Single-study evidence bases (including mega-trials) cannot be judged with respect to consistency. In that instance, use “Consistency unknown (single study).”
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome, based on the sufficiency of sample size and number of events.; - A body of evidence will generally be imprecise if the optimal information size (OIS) is not met. OIS refers to the minimum number of patients (and events when assessing dichotomous outcomes) needed for an evidence base to be considered adequately powered.; - If EPCs performed a meta-analysis, then EPCs may also consider whether the CI crossed a threshold for an MID.; - If a meta-analysis is infeasible or inappropriate, EPCs may consider the narrowness of the range of CIs or the significance level of p-values in the individual studies in the evidence base. | Score as one of two levels:; - Precise; - Imprecise; A precise estimate is one that would allow users to reach a clinically useful conclusion (e.g., treatment A is more effective than treatment B).
Reporting Bias | Reporting bias results from selectively publishing or reporting research findings based on the favorability of direction or magnitude of effect. It includes:; - Study publication bias, i.e., nonreporting of the full study.; - Selective outcome reporting bias, i.e., nonreporting (or incomplete reporting) of planned outcomes or reporting of unplanned outcomes.; - Selective analysis reporting bias, i.e., reporting of one or more favorable analyses for a given outcome while not reporting other, less favorable analyses.; Assessment of reporting bias for individual studies depends on many factors–e.g. availability of study protocols, unpublished study documents, and patient-level data. Detecting such bias is likely with access to all relevant documentation and data pertaining to a journal publication, but such access is rarely available. Because methods to detect reporting bias in observational studies are less certain, this guidance does not require EPCs to assess it for such studies. | Score as one of two levels:; - Suspected; - Undetected; Reporting bias is suspected when:; - Testing for funnel plot asymmetry demonstrates a substantial likelihood of bias,; And/or; - A qualitative assessment suggests the likelihood of missing studies, analyses, or outcomes data that may alter the conclusions from the reported evidence.; Undetected reporting bias includes all alternative scenarios.

Abbreviations: CI = confidence internal; EPC = Evidence-based Practice Center; MID = minimally important difference; OIS = optimal information size; RCT = randomized, controlled trial; SOE = strength of evidence

## Study Limitations Domain Definition

Scoring the study limitations domain is the essential starting place for grading strength of the body of evidence. It refers to the judgment that the findings from included studies of a treatment (or treatment comparison) for a given outcome are adequately protected against bias (i.e., have good internal validity), based on the design and conduct of those studies. That is, EPCs assess the ability of the evidence to yield an accurate estimate of the true effect without bias (nonrandom error).

## Directness Domain Definition

Directness of evidence expresses how closely available evidence measures an outcome of interest. Assessing directness has two parts: directness of outcomes and directness of comparisons. Applicability of evidence (external validity) is considered explicitly but separately from strength of evidence.

## Consistency Domain Definition

Consistency refers to the degree of similarity in the direction of effects or the degree of similarity in the effect sizes (magnitudes of effect) across individual studies within an evidence base. EPCs may choose which of these two notions of consistency (direction or magnitude) they are scoring; they should be explicit about this choice.

## Precision Domain Definition

Precision is the degree of certainty surrounding an estimate of effect with respect to an outcome. It is based on the potential for random error evaluated through the sufficiency of sample size and, in the case of dichotomous outcomes, the number of events. A precise body of evidence should enable decisionmakers to draw conclusions about whether one treatment is inferior, equivalent, or superior to another.

## Reporting Bias Definition

Reporting bias occurs when authors, journals, or both decide to publish or report research findings based on their direction or magnitude of effect. Table 2 defines the three main types of reporting bias that either authors or journals can introduce: publication bias and outcome and analysis reporting bias.

## Four Strength of Evidence Levels

The four levels of grades are intended to communicate to decisionmakers EPCs’ confidence in a body of evidence for a single outcome of a single treatment comparison. Although assigning a grade requires judgment, having a common understanding of the interpretation will be useful for helping EPCs as they conduct their own global assessment and for improving consistency across reviewers and EPCs.

Table F2 summarizes the four levels of grades that EPCs use for the overall assessment of the body of evidence. Grades are denoted high, moderate, low, and insufficient. They are not designated by Roman numerals or other symbols. EPCs should apply discrete grades and should not use designations such as “low to moderate” strength of evidence.

Table F2 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Each level has two components. The first, principal definition concerns the level of confidence that EPCs place in the estimate of effect (direction or magnitude of effect) for the benefit or harm; this equates to their judgment as to how much the evidence reflects a true effect. The second, subsidiary definition involves an assessment of the level of deficiencies in the body of evidence and belief in the stability of the findings, based on domain scores and a more holistic, summary appreciation of the possibly complex interaction among the individual domains.

Assigning a grade of high, moderate, or low implies that an evidence base is available from which to estimate an effect for either the benefit or the harm. The designations of high, moderate, and low should convey how confident EPCs would be about decisions based on evidence of differing grades, which can be based on either quantitative or qualitative assessment.

For comparative effectiveness questions, the comparison is typically a choice of either direction (A>B, A=B, A<B) or magnitude (difference between A and B). In some instances assigning different grades regarding the direction and the magnitude of an effect may be appropriate. An example of this situation is when studies consistently find that an intervention improves an outcome (e.g., apnea-hypopnea index is reduced by a statistically significant amount or beyond a minimally important difference), but the degree of heterogeneity about the estimate is high (e.g., range −10 to −46 events/minute; I^2^=86%).

The importance of the distinctions among high, moderate, and low levels (and the distinction with insufficient strength of evidence) can vary by the type of outcome, comparison, and decisionmaker. EPCs understand that some stakeholders may want to take action only when evidence is of high or moderate strength, whereas others may want to understand clearly the implications of low versus insufficient evidence. Even when strength of evidence is low or insufficient, consumers, clinicians, and policymakers may find themselves in the position of having to make choices and decisions, and they may consider factors other than the evidence from a specific systematic review, such as patient values and preferences, costs, or resources.

## Reference

1 (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.

1 The set of five required domains comprises the main constructs that Evidence-based Practice Centers (EPCs) should use for all major outcomes and comparisons of interest. As briefly defined below in Table F1, these domains represent related but separate concepts, and each is scored independently. The concepts are explained in more detail in this appendix.