# Appendix E Quality Rating Criteria

## Randomized Controlled Trials

### Criteria

- Initial assembly of comparable groups:
  ○ adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: intention-to-treat analysis.

## Definition of ratings based on above criteria

Good: | Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup at least 80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and intention-to-treat analysis is used.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and intention-to-treat analysis is done for randmised, controlled trials.
Poor: | Studies will be graded “poor” if any of the following fatal flaws exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and intention-to-treat is lacking.

## Diagnostic/Concordance Studies

### Criteria

- Test applied to an appropriate spectrum of patients (with and without disease/condition), avoiding case-control design
- Population tested was consecutive or random
- Clear eligibility criteria described and rigorous assessment of disease/condition
- Attrition reported and minimal loss to followup
- Test is adequately described and reproducible
- Test was validated in a second population group
- Test is an available standard case definition
- Diagnostic test is applied to all patients
- Blinding of outcome assessors to the reference standard

## Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 500) broad-spectrum patients with and without disease; study attempts to enroll a random or consecutive sample of patients who meet inclusion criteria screening cutoffs pre-stated.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (100 to 500 subjects) and a “medium” spectrum of patients (i.e. applicable to many settings where the diagnostic test would be applied).
Poor: | Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; small sample size (<100) of very narrow selected spectrum of patients (components of study not well described).

Sources: USPSTF Procedure Manual1, AHRQ Methods Guide,2 and AHRQ Methods Guide for Medical Test Reviews3

## References

1 U.S. Preventive Services Task Force. (2008). US Preventive Services Task Force Procedure Manual.
2 (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
3 (2012). Methods Guide for Medical Test Reviews.