# Appendix D List of Excluded Studies

Key to exclusion codes

Code | Reason for exclusion
2,3,4 | Excluded because the study does not address a Key Question or meet inclusion criteria, but full text pulled to provide background information
5 | Wrong population
6 | Wrong intervention
7 | Wrong outcomes
8 | Wrong study design for Key Question
9 | Wrong publication type
10 | Foreign language
11 | Not a human population
12 | Inadequate duration
13 | Study published before 1988
14 | Review not meeting our requirements

(1992). Alleged link between hepatitis B vaccine and chronic fatigue syndrome. CMAJ.
Campaign for an Irish ME Clinic.
(2002). Cognitive behavioral therapy and exercise for chronic fatigue syndrome. J Pain Pall Care Pharmacother.
From the Centers for Disease Control and Prevention. (1993). Inability of retroviral tests to identify persons with chronic fatigue syndrome, 1992. JAMA.
Government Response to the CFS/ME Independent Working Group’s Report.
Managing my M.E. What people with ME/CFS and their carers want from the UK’s health and social Services.
Mendelian genetic predisposition to weakly virulent mycobacterial infections in human. Human Genetics of Infectious Diseases.
(2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
(2013). MORE CFIDS/ME MARKERS AND IONIZING RADIATION.
A Report of the CFS/ME Working Group.
(1993). Report of the working group on the possible relationship between hepatitis B vaccination and the chronic fatigue syndrome. CMAJ.
Voices from the Shadows. Film.
Aaron LA, Arguelles LM, Ashton S, et al. (2002). Health and functional status of twins with chronic regional and widespread pain. J Rheumatol.
Aaron LA, Buchwald D. (2001). Fibromyalgia and other unexplained clinical conditions. Curr Rheumatol Rep.
Aaron LA, Buchwald D. (2001). A review of the evidence for overlap among unexplained clinical conditions. Ann Intern Med.
Aaron LA, Burke MM, Buchwald D. (2000). Overlapping conditions among patients with chronic fatigue syndrome, fibromyalgia, and temporomandibular disorder. Arch Intern Med.
Aaron LA, Herrell R, Ashton S, et al. (2001). Comorbid clinical conditions in chronic fatigue: a co-twin control study. J Gen Intern Med.
Abbey SE. (1996). Psychotherapeutic perspectives on chronic fatigue syndrome. Chronic fatigue syndrome: An integrative approach to evaluation and treatment.
Abbey SE, Garfinkel PE. (1991). Chronic fatigue syndrome and depression: cause, effect, or covariate. Rev Infect Dis.
Abbey SE, Toner BB, Garfinkel PE, et al. (1990). Self-report symptoms that predict major depression in patients with prominent physical symptoms. Int J Psychiatry Med.
Abdel-Khalek AM. (2008). Chronic fatigue syndrome and its association with obsession compulsion among a non-clinical sample using questionnaires. J Chronic Fatigue Syndr.
Adamowicz JL, Caikauskaite I, Friedberg F. (2014). Defining recovery in chronic fatigue syndrome: a critical review. Qual Life Res.
Adams D, Wu T, Yang X, et al. (2009). Traditional Chinese medicinal herbs for the treatment of idiopathic chronic fatigue and chronic fatigue syndrome. Cochrane Database Syst Rev.
Adolphe AB. (1988). Chronic fatigue syndrome: possible effective treatment with nifedipine. Am J Med.
Afari N, Buchwald D. (2003). Chronic fatigue syndrome: a review. Am J Psychiatry.
Agardy S. ‘Recovery’ in PACE, the 6 Minute Walking Test and Other Issues: How Well Can ‘Recovered’ Patients Walk?.
Akagi H, Klimes I, Bass C. (2001). Cognitive behavioral therapy for chronic fatigue syndrome in a general hospital - Feasible and effective. Gen Hosp Psychiatry.
Akarsu S, Tekin L, Ay H, et al. (2013). The efficacy of hyperbaric oxygen therapy in the management of chronic fatigue syndrome. Undersea Hyperb Med.
Alberts M, Smets EM, Vercoulen JH, et al. (1997). Ned Tijdschr Geneeskd.
Alraek T, Lee MS, Choi T-Y, et al. (2011). Complementary and alternative medicine for patients with chronic fatigue syndrome: a systematic review. BMC Altern Med.
Amel Kashipaz MR, Swinden D, Todd I, et al. (2003). Normal production of inflammatory cytokines in chronic fatigue and fibromyalgia syndromes determined by intracellular cytokine staining in short-term cultured blood mononuclear cells. Clin Exp Immunol.
Amsterdam JD, Shults J, Rutherford N. (2008). Open-label study of s-citalopram therapy of chronic fatigue syndrome and co-morbid major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry.
Andersen MM, Permin H, Albrecht F. (2004). Illness and disability in Danish Chronic Fatigue Syndrome patients at diagnosis and 5-year follow-up. J Psychosom Res.
Anderson JS, Ferrans CE. (1997). The quality of life of persons with chronic fatigue syndrome. J Nerv Ment Dis.
Anderson VR, Jason LA, Hlavaty LE. (2014). A qualitative natural history study of ME/CFS in the community. Health Care Women Int.
Andersson M, Bagby J, Dyrehag L, et al. (1998). Effects of staphylococcus toxoid vaccine on pain and fatigue in patients with fibromyaigia/chronic fatigue syndrome. Eur J Pain.
Andersson M, Bagby JR, Dyrehag L, et al. (1998). Effects of staphylococcus toxoid vaccine on pain and fatigue in patients with fibromyalgia/chronic fatigue syndrome. Eur J Pain.
Anfinson TJ. (1995). Diagnostic assessment of chronic fatigue syndrome. Medical-psychiatric practice.
Antiel RM, Caudill JS, Burkhardt BEU, et al. (2011). Iron insufficiency and hypovitaminosis D in adolescents with chronic fatigue and orthostatic intolerance. South Med J.
Appleby L. (1995). Aerobic exercise and Fluoxetine in the treatment of chronic fatigue syndrome. National Research Register.
Arnold DL, Bore PJ, Radda GK, et al. (1984). Excessive intracellular acidosis of skeletal muscle on exercise in a patient with a post-viral exhaustion/fatigue syndrome. A 31P nuclear magnetic resonance study. Lancet.
Arroll MA, Senior V. (2008). Individuals’ experience of chronic fatigue syndrome/myalgic encephalomyelitis: An interpretative phenomenological analysis. Psychol Health.
Ash-Bernal R, Wall C, Komaroff AL, et al. (1995). Vestibular function test anomalies in patients with chronic fatigue syndrome. Acta Otolaryngol (Stockh).
Awdry R. (1996). Homoeopathy may help ME. International Journal of Alternative and Complementary Medicine.
Badham SP, Hutchinson CV. (2013). Characterising eye movement dysfunction in myalgic encephalomyelitis/chronic fatigue syndrome. Graefes Arch Clin Exp Ophthalmol.
Bagnall AM, Whiting P, Richardson R, et al. (2002). Interventions for the treatment and management of chronic fatigue syndrome/myalgic encephalomyelitis. Qual Saf Health Care.
Bakker RJ, van de Putte EM, Kuis W, et al. (2011). Effects of an educational video film in fatigued children and adolescents: a randomised controlled trial. Arch Dis Child.
Baraniuk JN, Petrie KN, Le U, et al. (2005). Neuropathology in rhinosinusitis. Am J Respir Crit Care Med.
Barron DF, Cohen BA, Geraghty MT, et al. (2002). Joint hypermobility is more common in children with chronic fatigue syndrome than in healthy controls. J Pediatr.
Baschetti R. (2000). The 1microg Synacthen test in chronic fatigue syndrome. Clin Endocrinol (Oxf).
Baschetti R. (2001). Cognitive behaviour therapy and chronic fatigue syndrome. Br J Gen Pract.
Baschetti R. (1999). Investigations of hydrocortisone and fludrocortisone in the treatment of chronic fatigue syndrome. J Clin Endocrinol Metab.
Baschetti R. (1998). Treating chronic fatigue with exercise. Results are contradictory for patients meeting different diagnostic criteria. BMJ.
Basu R, O’Quinn DB, Silberger DJ, et al. (2012). Th22 cells are an important source of IL-22 for host protection against enteropathogenic bacteria. Immunity.
Bates DW, Buchwald D, Lee J, et al. (1995). Clinical laboratory test findings in patients with chronic fatigue syndrome. Arch Intern Med.
Bates DW, Schmitt W, Buchwald D, et al. (1993). Prevalence of fatigue and chronic fatigue syndrome in a primary care practice. Arch Intern Med.
Bazelmans E, Prins J, Bleijenberg G. (2002). Cognitive behavior therapy for active and for passive CFS patients. Gedragstherapie.
Bazelmans E, Prins J, Bleijenberg G. (2006). Cognitive Behavior Therapy for Relatively Active and for Passive Chronic Fatigue Syndrome Patients. Cogn Behav Pract.
Beck AT, Steer RA, Carbin MG. (1988). Psychometric properties of the Beck Depression Inventory: Twenty-five years of evaluation. Clin Psychol Rev.
Beh HC, Connelly N, Charles M. (1997). Effect of noise stress on chronic fatigue syndrome patients. J Nerv Ment Dis.
Behan P, Behan WH. (1990). Essential Fatty Acids in the treatment of postviral fatigue syndrome. Horrobin DF, editor. Omega-6 Essential Fatty Acids: Pathophysiology and Roles in Clinical Medicine.
Behan P, Haniffah B, Doogan D, et al. (1994). A Pilot Study of Sertraline for the Treatment of Chronic Fatigue Syndrome. Clin Infect Dis.
Behan PO, Behan WM, Horrobin D. (1990). Effect of high doses of essential fatty acids on the postviral fatigue syndrome. Acta Neurol Scand.
Bell DS. (2008). ME/CFS as a Mitochondrial Disease. Lyndonville News.
Bell IR, Szarek MJ, Dicenso DR, et al. (1999). Patterns of waking EEG spectral power in chemically intolerant individuals during repeated chemical exposures. Int J Neurosci.
Bennett AL, Fagioli LR, Schur PH, et al. (1996). Immunoglobulin subclass levels in chronic fatigue syndrome. J Clin Immunol.
Bentall RP, Powell P, Nye FJ, et al. (2002). Predictors of response to treatment for chronic fatigue syndrome. Br J Psychiatry.
Bentler SE, Hartz AJ, Kuhn EM. (2005). Prospective observational study of treatments for unexplained chronic fatigue. J Clin Psychiatry.
Bergner M, Bobbitt RA, Carter WB, et al. (1981). The Sickness Impact Profile: development and final revision of a health status measure. Med Care.
Beurskens AJ, Bultmann U, Kant I, et al. (2000). Fatigue among working people: validity of a questionnaire measure. Occup Environ Med.
Bhattacharjee M, Botting CH, Sillanpaa MJ. (2008). Bayesian biomarker identification based on marker-expression proteomics data. Genomics.
Biswal B, Kunwar P, Natelson BH. (2011). Cerebral blood flow is reduced in chronic fatigue syndrome as assessed by arterial spin labeling. J Neurol Sci.
Bjelland I, Dahl AA, Haug TT, et al. (2002). The validity of the Hospital Anxiety and Depression Scale. An updated literature review. J Psychosom Res.
Black CD, McCully KK. (2005). Time course of exercise induced alterations in daily activity in chronic fatigue syndrome. Dyn Med.
Black CD, O’Connor PJ, McCully KK. (2005). Increased daily physical activity and fatigue symptoms in chronic fatigue syndrome. Dyn Med.
Blakely AA, Howard RC, Sosich RM, et al. (1991). Psychiatric symptoms, personality and ways of coping in chronic fatigue syndrome. Psychol Med.
Blazquez A, Guillamo E, Javierre C. (2010). Preliminary experience with dance movement therapy in patients with chronic fatigue syndrome. The Arts in Psychotherapy.
Bleijenberg G. (2008). The effectiveness of cognitive behavioural therapy in groups for patients with Chronic Fatigue Syndrome (CFS): a randomised controlled study [ISRCTN15823716]. controlled trialscom.
Bleijenberg G. (2008). The effectiveness of Self-instructions in the treatment of patients with Chronic Fatigue Syndrome (CFS): a randomised controlled study [ISRCTN27293439]. controlled trialscom.
Blenkiron P, Edwards R, Lynch S. (1999). Associations between perfectionism, mood, and fatigue in chronic fatigue syndrome: a pilot study. J Nerv Ment Dis.
Blockmans D, Persoons P, Van Houdenhove B, et al. (2006). Does methylphenidate reduce the symptoms of chronic fatigue syndrome?. Am J Med.
Boda WL, Natelson BH, Sisto SA, et al. (1995). Gait abnormalities in chronic fatigue syndrome. J Neurol Sci.
Bombardier CH, Buchwald D. (1996). Chronic fatigue, chronic fatigue syndrome, and fibromyalgia. Disability and health-care use. Med Care.
Bombardier CH, Buchwald D. (1995). Outcome and prognosis of patients with chronic fatigue vs chronic fatigue syndrome. Arch Intern Med.
Boneva RS, Decker MJ, Maloney EM, et al. (2007). Higher heart rate and reduced heart rate variability persist during sleep in chronic fatigue syndrome: a population-based study. Auton Neurosci.
Boneva RS, Lin J-MS, Maloney EM, et al. (2009). Use of medications by people with chronic fatigue syndrome and healthy persons: a population-based study of fatiguing illness in Georgia. Health Qual Life Outcomes.
Borish L, Schmaling K, DiClementi JD, et al. (1998). Chronic fatigue syndrome: identification of distinct subgroups on the basis of allergy and psychologic variables. J Allergy Clin Immunol.
Bou-Holaigah I, Rowe PC, Kan J, et al. (1995). The relationship between neurally mediated hypotension and the chronic fatigue syndrome. JAMA.
Bowling A, Bond M, Jenkinson C, et al. (1999). Short Form 36 (SF-36) Health Survey questionnaire: which normative data should be used? Comparisons between the norms provided by the Omnibus Survey in Britain, the Health Survey for England and the Oxford Healthy Life Survey. Journal of Public Health.
Bowman MA, Kirk JK, Michielutte R, et al. (1997). Use of amantadine for chronic fatigue syndrome. Arch Intern Med.
Bradley AS, Ford B, Bansal AS. (2013). Altered functional B cell subset populations in patients with chronic fatigue syndrome compared to healthy controls. Clin Exp Immunol.
Brenu E, Johnston S, Hardcastle S, et al. (2013). Immune abnormalities in patients meeting new diagnostic criteria for chronic fatigue syndrome/Myalgic Encephalomyelitis. J Mol Biomark Diagn.
Brenu EW, Ashton KJ, van Driel M, et al. (2012). Cytotoxic lymphocyte microRNAs as prospective biomarkers for Chronic Fatigue Syndrome/Myalgic Encephalomyelitis. J Affect Disord.
Brenu EW, van Driel ML, Staines DR, et al. (2012). Longitudinal investigation of natural killer cells and cytokines in chronic fatigue syndrome/myalgic encephalomyelitis. J Transl Med.
Brenu EW, van Driel ML, Staines DR, et al. (2011). Immunological abnormalities as potential biomarkers in Chronic Fatigue Syndrome/Myalgic Encephalomyelitis. J Transl Med.
Brewer JH, Thrasher JD, Straus DC, et al. (2013). Detection of mycotoxins in patients with chronic fatigue syndrome. Toxins (Basel).
Brimacombe M, Helmer D, Natelson BH. (2002). Clinical differences exist between patients fulfilling the 1988 and 1994 case definitions of chronic fatigue syndrome. J Clin Psychol Med Settings.
Bringsli GJ, Gilje A, Wold BKG. THE NORWEGIAN ME ASSOCIATION NATIONAL SURVEY Abridged ENGLISH VERSION.
Brkic S, Tomic S, Maric D, et al. (2010). Lipid peroxidation is elevated in female patients with chronic fatigue syndrome. Med Sci Monit.
Broadbent DE, Cooper PF, FitzGerald P, et al. (1982). The Cognitive Failures Questionnaire (CFQ) and its correlates. Br J Clin Psychol.
Broderick G. (2012). A moving target: Taking aim at the regulatory dynamics of illness. Brain Behav Immun.
Broderick G, Craddock RC, Whistler T, et al. (2006). Identifying illness parameters in fatiguing syndromes using classical projection methods. Pharmacogenomics.
Brooks J, King N, Wearden A. (2014). Couples’ experiences of interacting with outside others in chronic fatigue syndrome: A qualitative study. Chronic Illn.
Brooks JC, Roberts N, Whitehouse G, et al. (2000). Proton magnetic resonance spectroscopy and morphometry of the hippocampus in chronic fatigue syndrome. Br J Radiol.
Brostoff J. (2000). A phase II, randomised, placebo controlled study to assess the safety and efficacy of anti cholineskinase drugs in patients with a diagnosis of chronic fatigue syndrome. National Research Register.
Brouwer B, Packer T. (1994). Corticospinal excitability in patients diagnosed with chronic fatigue syndrome. Muscle Nerve.
Brouwers FM, Van Der Werf S, Bleijenberg G, et al. (2002). The effect of a polynutrient supplement on fatigue and physical activity of patients with chronic fatigue syndrome: a double-blind randomized controlled trial. QJM.
Brown AA, Evans MA, Jason LA. (2013). Examining the energy envelope and associated symptom patterns in chronic fatigue syndrome: Does coping matter?. Chronic Illn.
Brown M, Kaplan C, Jason L. (2012). Factor analysis of the Beck Depression Inventory-II with patients with chronic fatigue syndrome. J Health Psychol.
Brown MM, Brown AA, Jason LA. (2010). Illness duration and coping style in chronic fatigue syndrome. Psychol Rep.
Brunello N, Akiskal H, Boyer P, et al. (1999). Dysthymia: clinical picture, extent of overlap with chronic fatigue syndrome, neuropharmacological considerations, and new therapeutic vistas. J Affect Disord.
Brurberg KG, Fonhus MS, Larun L, et al. (2014). Case definitions for chronic fatigue syndrome/myalgic encephalomyelitis (CFS/ME): a systematic review. BMJ Open.
Buchwald D, Herrell R, Ashton S, et al. (1999). The Chronic Fatigue Twin Registry: method of construction, composition, and zygosity assignment. Twin Res.
Buchwald D, Herrell R, Ashton S, et al. (2001). A twin study of chronic fatigue. Psychosom Med.
Buchwald D, Pearlman T, Umali J, et al. (1996). Functional status in patients with chronic fatigue syndrome, other fatiguing illnesses, and healthy individuals. Am J Med.
Buchwald D, Umali P, Umali J, et al. (1995). Chronic fatigue and the chronic fatigue syndrome: prevalence in a Pacific Northwest health care system. Ann Intern Med.
Buchwald D, Wener MH, Pearlman T, et al. (1997). Markers of inflammation and immune activation in chronic fatigue and chronic fatigue syndrome. J Rheumatol.
Burckhardt CS, Anderson KL. (2003). The Quality of Life Scale (QOLS): reliability, validity, and utilization. Health Qual Life Outcomes.
Burckhardt CS, Clark SR, Bennett RM. (1991). The fibromyalgia impact questionnaire: development and validation. J Rheumatol.
Burgess M, Chalder T. Cognitive behaviour therapy for adults with chronic fatigue syndrome: Outpatient v telephone sessions; a randomised controlled trial. 32nd Congress of the British Association for Behavioural and Cognitive Psychotherapies.
Burnet RB, Chatterton BE. (2004). Gastric emptying is slow in chronic fatigue syndrome. BMC Gastroenterol.
Burton AR, Rahman K, Kadota Y, et al. (2010). Reduced heart rate variability predicts poor sleep quality in a case-control study of chronic fatigue syndrome. Exp Brain Res.
Busichio K, Tiersky LA, Deluca J, et al. (2004). Neuropsychological deficits in patients with chronic fatigue syndrome. J Int Neuropsychol Soc.
White C Michael, Ip Stanley, McPheeters Melissa, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Methods Guide for Comparative Effectiveness Reviews.
Cairns R, Hotopf M. (2005). A systematic review describing the prognosis of chronic fatigue syndrome. Occup Med.
Cameron B, Galbraith S, Zhang Y, et al. (2007). Gene expression correlates of postinfective fatigue syndrome after infectious mononucleosis. J Infect Dis.
Campion P. (1998). Should general practitioners manage chronic fatigue syndrome? A controlled trial. Current Controlled Trials.
Camus F, Henzel D, Janowski M, et al. (1992). Unexplained fever and chronic fatigue: abnormal circadian temperature pattern. Eur J Med.
Capuron L, Welberg L, Heim C, et al. (2006). Cognitive dysfunction relates to subjective report of mental fatigue in patients with chronic fatigue syndrome. Neuropsychopharmacology.
Carlo-Stella N, Bozzini S, De Silvestri A, et al. (2009). Molecular study of receptor for advanced glycation endproduct gene promoter and identification of specific HLA haplotypes possibly involved in chronic fatigue syndrome. Int J Immunopathol Pharmacol.
Carmel L, Efroni S, White PD, et al. (2006). Gene expression profile of empirically delineated classes of unexplained chronic fatigue. Pharmacogenomics.
Carruthers BM, Jain AK, de Meirleir KL, et al. (2003). Myalgic Encephalomyelitis/Chronic Fatigue Syndrome: Clinical Working Case Definition, Diagnostic and Treatment Protocols. J Chronic Fatigue Syndr.
Carruthers BM, van de Sande MI, De Meirleir KL, et al. (2011). Myalgic encephalomyelitis: International Consensus Criteria. J Intern Med.
Carruthers BM, van de Sande MI, De Meirleir K, et al. (2012). Myalgic Encephalomyelitis. Adult & Paediatric: International Consensus Primer for Medical Practitioners.
Carson KV, Labiszewski NA, Brinn MP, et al. (2012). Consumer guidelines for chronic disease management. Cochrane Database Syst Rev.
Carver CS. (1997). You want to measure coping but your protocol’too long: Consider the brief cope. Int J Behav Med.
Casado B, Zanone C, Annovazzi L, et al. (2005). Urinary electrophoretic profiles from chronic fatigue syndrome and chronic fatigue syndrome/fibromyalgia patients: a pilot study for achieving their normalization. J Chromatogr B Analyt Technol Biomed Life Sci.
Castell BD, Kazantzis N, Moss-Morris RE. (2011). Cognitive behavioral therapy and graded exercise for chronic fatigue syndrome: A meta-analysis. Clin Psychol Sci Prac.
Castro-Marrero J, Cordero MD, Saez-Francas N, et al. (2013). Could mitochondrial dysfunction be a differentiating marker between chronic fatigue syndrome and fibromyalgia?. Antioxid Redox Signal.
Cella M, Chalder T. (2010). Measuring fatigue in clinical and community settings. J Psychosom Res.
Cella M, Chalder T, White PD. (2011). Does the heterogeneity of chronic fatigue syndrome moderate the response to cognitive behaviour therapy? An exploratory study. Psychother Psychosom.
Cella M, Sharpe M, Chalder T. (2011). Measuring disability in patients with chronic fatigue syndrome: reliability and validity of the Work and Social Adjustment Scale. J Psychosom Res.
Cella M, White PD, Sharpe M, et al. (2013). Cognitions, behaviours and co-morbid psychiatric diagnoses in patients with chronic fatigue syndrome. Psychol Med.
Center for Drug Evaluation and Research. (2013). The Voice of the Patient: A series of reports from the U.S. Food and Drug Administration’s (FDA’s) Patient-Focused Drug Development Initiative. Chronic Fatigue Syndrome and Myalgic Encephalomyelitis.
Centers for Disease C, Prevention. (1993). Inability of retroviral tests to identify persons with chronic fatigue syndrome, 1992. MMWR Morb Mortal Wkly Rep.
Chalder T, Berelowitz G, Pawlikowska T, et al. (1993). Development of a fatigue scale. J Psychosom Res.
Chalder T, Deale A, Wessely S. (1995). Cognitive behavioral therapy for chronic fatigue syndrome. Clin Infect Dis.
Chalder T, Godfrey E, Ridsdale L, et al. (2003). Predictors of outcome in a fatigued population in primary care following a randomized controlled trial. Psychol Med.
Chalder T, Power MJ, Wessely S. (1996). Chronic fatigue in the community: ‘a question of attribution’. Psychol Med.
Chalder T, Wallace P, Wessley S. (1997). Self-help treatment of chronic fatigue in the community: A randomized controlled trial. Br J Health Psychol.
Chalder T, Wessely S, Wallace P, et al. (1995). Viral illness and chronic fatigue (syndrome). Lancet.
Chalmers RA, Jones MG, Goodwin CS, et al. (2006). CFSUM1 and CFSUM2 in urine from patients with chronic fatigue syndrome are methodological artefacts. Clin Chim Acta.
Chambers D, Bagnall A-M, Hempel S, et al. (2006). Interventions for the treatment, management and rehabilitation of patients with chronic fatigue syndrome/myalgic encephalomyelitis: an updated systematic review. J R Soc Med.
Chaudhuri A. (2001). Cognitive behaviour therapy for chronic fatigue syndrome. Lancet.
Chaudhuri A. (2001). Patient education to encourage graded exercise in chronic fatigue syndrome. Trial has too many shortcomings. BMJ.
Chaudhuri A, Condon BR, Gow JW, et al. (2003). Proton magnetic resonance spectroscopy of basal ganglia in chronic fatigue syndrome. Neuroreport.
Chaudhuri A, Gow JW, Behan PO. (2008). Neurobiology of chronic fatigue syndrome. Fatigue science for human health.
Cheverton DP. (1992). Tetracyclines in myalgic encephalomyelitis. Suid-Afrikaanse Tydskrif Vir Geneeskunde.
Chilton SA. (1996). Cognitive behaviour therapy for the chronic fatigue syndrome. Evening primrose oil and magnesium have been shown to be effective. BMJ.
Cho HJ, Bhugra D, Wessely S. (2008). ‘Physical or psychological?’-a comparative study of causal attribution for chronic fatigue in Brazilian and British primary care patients. Acta Psychiatr Scand.
Cho HJ, Hotopf M, Wessely S. (2005). The placebo response in the treatment of chronic fatigue syndrome: a systematic review and meta-analysis. Psychosom Med.
Chu L, Friedberg F, Friedman KJ, et al. (2012). Exercise and chronic fatigue syndrome: maximize function, minimize post-exertional malaise. Eur J Clin Invest.
Ciccone DS, Busichio K, Vickroy M, et al. (2003). Psychiatric morbidity in the chronic fatigue syndrome: are patients with personality disorder more physically impaired?. J Psychosom Res.
Ciccone DS, Chandler HK, Natelson BH. (2010). Illness trajectories in the chronic fatigue syndrome: a longitudinal study of improvers versus non-improvers. J Nerv Ment Dis.
Ciregia F, Giusti L, Da Valle Y, et al. (2013). A multidisciplinary approach to study a couple of monozygotic twins discordant for the chronic fatigue syndrome: a focus on potential salivary biomarkers. J Transl Med.
Clague JE, Edwards RH, Jackson MJ. (1992). Intravenous magnesium loading in chronic fatigue syndrome. Lancet.
Clark C, Goodwin L, Stansfeld SA, et al. (2011). Premorbid risk markers for chronic fatigue syndrome in the 1958 British birth cohort. Br J Psychiatry.
Clark LV, White PD. (2005). The role of deconditioning and therapeutic exercise in chronic fatigue syndrome (CFS). J Ment Health.
Clark MR, Katon W, Russo J, et al. (1995). Chronic fatigue: risk factors for symptom persistence in a 2 1/2-year follow-up study. Am J Med.
Cleare AJ, Blair D, Chambers S, et al. (2001). Urinary free cortisol in chronic fatigue syndrome. Am J Psychiatry.
Cleare AJ, Heap E, Malhi GS, et al. (1999). Low-dose hydrocortisone in chronic fatigue syndrome: a randomised crossover trial. Lancet.
Cleare AJ, Messa C, Rabiner EA, et al. (2005). Brain 5-HT1A receptor binding in chronic fatigue syndrome measured using positron emission tomography and [11C]WAY-100635. Biol Psychiatry.
Cleare AJ, Miell J, Heap E, et al. (2001). Hypothalamo-pituitary-adrenal axis dysfunction in chronic fatigue syndrome, and the effects of low-dose hydrocortisone therapy. J Clin Endocrinol Metab.
Cleare AJ, O’Keane V, Miell JP. (2004). Levels of DHEA and DHEAS and responses to CRH stimulation and hydrocortisone treatment in chronic fatigue syndrome. Psychoneuroendocrinology.
Cockshell SJ, Mathias JL. (2013). Cognitive Functioning in People With Chronic Fatigue Syndrome: A Comparison Between Subjective and Objective Measures. Neuropsychology.
Coetzer P, Lockyer I, Schorn D, et al. (2000). Quantitative disability evaluation of syndromes presenting with chronic fatigue. Suid-Afrikaanse Tydskrif Vir Geneeskunde.
Cohen S, Kamarck T, Mermelstein R. (1983). A global measure of perceived stress. J Health Soc Behav.
Collin C, Wade DT, Davies S, et al. (1988). The Barthel ADL Index: a reliability study. Int Disabil Stud.
Collin SM, Crawley E, May MT, et al. (2011). The impact of CFS/ME on employment and productivity in the UK: a cross-sectional study based on the CFS/ME national outcomes database. BMC Health Serv Res.
Collinge W, Yarnold P, Raskin E. (1998). Use of mind/body selfhealing practice predicts positive health transition in chronic fatigue syndrome: a controlled study. Subtle Energies & Energy Medicine.
Colquhoun D, Senn S. (2000). Is NADH effective in the treatment of chronic fatigue syndrome?. Ann Allergy Asthma Immunol.
Connolly S, Smith DG, Doyle D, et al. (1993). Chronic fatigue: electromyographic and neuropathological evaluation. J Neurol.
Constant EL, Adam S, Gillain B, et al. (2011). Cognitive deficits in patients with chronic fatigue syndrome compared to those with major depressive disorder and healthy controls. Clin Neurol Neurosurg.
Conti F, Magrini L, Priori R, et al. (1996). Eosinophil cationic protein serum levels and allergy in chronic fatigue syndrome. Allergy.
Conti F, Priori R, De Petrillo G, et al. (1994). Prevalence of chronic fatigue syndrome in Italian patients with persistent fatigue. Ann Ital Med Int.
Cook DB, Lange G, DeLuca J, et al. (2001). Relationship of brain MRI abnormalities and physical functional status in chronic fatigue syndrome. Int J Neurosci.
Cook DB, O’Connor PJ, Lange G, et al. (2007). Functional neuroimaging correlates of mental fatigue induced by cognition among chronic fatigue syndrome patients and controls. Neuroimage.
Cooper DM, Radom-Aizik S, Schwindt C, et al. (2007). Dangerous exercise: lessons learned from dysregulated inflammatory responses to physical activity. J Appl Physiol (1985).
Cooper L. (2000). Report on Survey of Members of Local ME Groups.
Cope H, Mann A, Pelosi A, et al. (1996). Psychosocial risk factors for chronic fatigue and chronic fatigue syndrome following presumed viral illness: a case-control study. Psychol Med.
Cope H, Pernet A, Kendall B, et al. (1995). Cognitive functioning and magnetic resonance imaging in chronic fatigue. Br J Psychiatry.
Cordero DL, Sisto SA, Tapp WN, et al. (1996). Decreased vagal power during treadmill walking in patients with chronic fatigue syndrome. Clin Auton Res.
Corradi KM, Jason LA, Torres-Harding SR. (2006). Exploratory Subgrouping in CFS: Infectious, Inflammatory, and Other. Advances in psychology research.
Costa DC, Tannock C, Brostoff J. (1995). Brainstem perfusion is impaired in chronic fatigue syndrome. QJM.
Costigan A, Elliott C, McDonald C, et al. (2010). Orthostatic symptoms predict functional capacity in chronic fatigue syndrome: implications for management. QJM.
Cox DL. (2002). Chronic fatigue syndrome: An evaluation of an occupational therapy inpatient intervention. Br J Occup Ther.
Cox DL, Findley LJ. (1994). Is chronic fatigue syndrome treatable in an NHS environment?. Clin Rehabil.
Cox IM, Campbell MJ, Dowson D. (1991). Red blood cell magnesium and chronic fatigue syndrome. Lancet.
Crawley E. (2012). Comparing specialist medical care with specialist medical care plus the Lightning Process for Chronic Fatigue Syndrome or Myalgic Encephalopathy (CFS/ME) - a randomised controlled trial [ISRCTN81456207]. Controlled trials.com.
Crawley E. (2014). The epidemiology of chronic fatigue syndrome/myalgic encephalitis in children. Arch Dis Child.
Crawley E, Collin SM, White PD, et al. (2013). Treatment outcome in adults with chronic fatigue syndrome: a prospective study in England based on the CFS/ME National Outcomes Database. QJM.
Crawley EM, Emond AM, Sterne JA. (2011). Unidentified Chronic Fatigue Syndrome/myalgic encephalomyelitis (CFS/ME) is a major cause of school absence: surveillance outcomes from school-based clinics. BMJ Open.
Curriu M, Carrillo J, Massanella M, et al. (2013). Screening NK-, B- and T-cell phenotype and function in patients suffering from Chronic Fatigue Syndrome. J Transl Med.
Dansie EJ, Furberg H, Afari N, et al. (2012). Conditions comorbid with chronic fatigue in a population-based sample. Psychosomatics.
Darbishire L, Ridsdale L, Seed PT. (2003). Distinguishing patients with chronic fatigue from those with chronic fatigue syndrome: a diagnostic study in UK primary care. Br J Gen Pract.
Darbishire L, Seed P, Ridsdale L. (2005). Predictors of outcome following treatment for chronic fatigue. Br J Psychiatry.
Davenport TE, Stevens SR, VanNess MJ, et al. (2010). Conceptual model for physical therapist management of chronic fatigue syndrome/myalgic encephalomyelitis. Phys Ther.
Davis SD, Kator SF, Wonnett JA, et al. (2000). Neurally mediated hypotension in fatigued Gulf War veterans: a preliminary report. Am J Med Sci.
De Becker P, Dendale P, De Meirleir K, et al. (1998). Autonomic testing in patients with chronic fatigue syndrome. Am J Med.
De Becker P, McGregor N, De Meirleir K. (2001). A definition-based analysis of symptoms in a large cohort of patients with chronic fatigue syndrome. J Intern Med.
De Becker P, Nijs J, Van Hoof E, et al. A double-blind, placebo-controlled study of acclydine in combination with amino acids in patients with chronic fatigue syndrome. AHMF Proceedings, “Myalgic Encephalopathy/Chronic Fatigue Syndrome ‘The Medical Practitioners’ Challenge in 2001”.
De Becker P, Roeykens J, Reynders M, et al. (2000). Exercise capacity in chronic fatigue syndrome. Arch Intern Med.
de Lange FP, Kalkman JS, Bleijenberg G, et al. (2004). Neural correlates of the chronic fatigue syndrome--an fMRI study. Brain.
de Lange FP, Koers A, Kalkman JS, et al. (2008). Increase in prefrontal cortical volume following cognitive behavioural therapy in patients with chronic fatigue syndrome. Brain.
De Lorenzo F, Hargreaves J, Kakkar VV. (1998). Phosphate diabetes in patients with chronic fatigue syndrome. Postgrad Med J.
De Lorenzo F, Hargreaves J, Kakkar VV. (1996). Possible relationship between chronic fatigue and postural tachycardia syndromes. Clin Auton Res.
De Lorenzo F, Kakkar VV. (1996). Twenty-four-hour urine analysis in patients with orthostatic hypotension and chronic fatigue syndrome (CFS). Aust N Z J Med.
De Meirleir K, Bisbal C, Campine I, et al. (2000). A 37 kDa 2–5A binding protein as a potential biochemical marker for chronic fatigue syndrome. Am J Med.
De Vinci C, Levine PH, Pizza G, et al. (1996). Lessons from a pilot study of transfer factor in chronic fatigue syndrome. Biotherapy.
Deale A. (1999). CBT versus relaxation for chronic fatigue syndrome: outcome at 5 year follow-up. National Research Register.
Deale A, Chalder T, Wessely S. (1998). Illness beliefs and treatment outcome in chronic fatigue syndrome. J Psychosom Res.
Deale A, Chalder T, Wessely S. (1998). “Randomised, double-blind, placebo-controlled trial of fluoxetine and graded exercise for chronic fatigue syndrome”: Commentary. Br J Psychiatry.
Deale A, David AS. (1994). Chronic fatigue syndrome: evaluation and management. J Neuropsychiatry Clin Neurosci.
Deary IJ. (1999). A taxonomy of medically unexplained symptoms. J Psychosom Res.
Dechéne L. Mitochondrial Dysfunction, Post-Exertional Malaise and CFS/ME.
DeFreitas E, Hilliard B, Cheney PR, et al. (1991). Retroviral sequences related to human T-lymphotropic virus type II in patients with chronic fatigue immune dysfunction syndrome. Proc Natl Acad Sci U S A.
Demitrack MA, Dale JK, Straus SE, et al. (1991). Evidence for impaired activation of the hypothalamic-pituitary-adrenal axis in patients with chronic fatigue syndrome. J Clin Endocrinol Metab.
Demitrack MA, Gold PW, Dale JK, et al. (1992). Plasma and cerebrospinal fluid monoamine metabolism in patients with chronic fatigue syndrome: preliminary findings. Biol Psychiatry.
Dimitrov M, Grafman J. (1997). Neuropsychological assessment of chronic fatigue syndrome. J Chronic Fatigue Syndr.
Dinos S, Khoshaba B, Ashby D, et al. (2009). A systematic review of chronic fatigue, its syndromes and ethnicity: prevalence, severity, co-morbidity and coping. Int J Epidemiol.
Dissemination CfRa. (2013). Complementary and alternative medicine treatments in the management of chronic fatigue syndrome: a systematic review of randomized controlled trials (Provisional abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Defining and managing chronic fatigue syndrome (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2014). Defining and managing chronic fatigue syndrome (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Efficacy of cognitive behavioral therapy for chronic fatigue syndrome: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). How to exercise people with chronic fatigue syndrome: evidence-based practice guidelines (Provisional abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). A meta analysis on randomized controlled trials of acupuncture treatment of chronic fatigue syndrome (Provisional abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). The placebo response in the treatment of chronic fatigue syndrome: a systematic review and meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Prognosis of fatigue: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Psychological treatment of patients with chronic toxic encephalopathy: lessons from studies of chronic fatigue and whiplash (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Psychosocial treatments for multiple unexplained physical symptoms: a review of the literature (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Rehabilitation programs for individuals with chronic fatigue syndrome: a review (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Systematic review and meta-analysis of interventions for postoperative fatigue (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Systematic review of the current literature related to disability and chronic fatigue syndrome (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2014). Systematic review of the current literature related to disability and chronic fatigue syndrome (Structured abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). Treating chronic fatigue syndrome: a study into the scientific evidence for pharmacological treatments (Provisional abstract). Database of Abstracts of Reviews of Effects.
Dissemination CfRa. (2013). The treatment and management of chronic fatigue syndrome/myalgic encephalomyelitis in adults and children (Structured abstract). Database of Abstracts of Reviews of Effects.
Dolors Estrada M, Parada A. (2001). Chronic Fatigue Syndrome. CAHTA, Catalan Agency for Health Technology Assessment and Research.
Dooley DP. (1992). Commercial laboratory testing for chronic fatigue syndrome. JAMA.
Dowsett E, Goudsmit E, Macintyre A, et al. (1994). Report from The National Task Force on Chronic Fatigue Syndrome (CFS), Post Viral Fatigue Syndrome (PVFS), Myalgic Encephalomyelitis (ME). Westcare.
Du Pre S. TOP 10 TESTS for MYALGIC ENCEPHALOMYELITIS & CFS LABELED PATIENTS.
Duff K. (2003). Social effects of chronic disorders. Handbook of chronic fatigue syndrome.
Duffy FH, McAnulty GB, McCreary MC, et al. (2011). EEG spectral coherence data distinguish chronic fatigue syndrome patients from healthy controls and depressed patients--a case control study. BMC Neurol.
Dunstan RH, Donohoe M, Taylor W, et al. (1995). A preliminary investigation of chlorinated hydrocarbons and chronic fatigue syndrome. Med J Aust.
Duprez DA, De Buyzere ML, Drieghe B, et al. (1998). Long- and short-term blood pressure and RR-interval variability and psychosomatic distress in chronic fatigue syndrome. Clin Sci.
Dykman KD, Tone C, Ford C, et al. (1998). The effects of nutritional supplements on the symptoms of fibromyalgia and chronic fatigue syndrome. Integr Physiol Behav Sci.
Edmonds M, McGuire H, Price J. (2004). Exercise therapy for chronic fatigue syndrome. Cochrane Database Syst Rev.
Edmonds M, McGuire H, Price JR. (2013). Exercise therapy for chronic fatigue syndrome. Cochrane Database Syst Rev.
Edwards CR, Thompson AR, Blair A. (2007). An ‘overwhelming illness’: women’s experiences of learning to live with chronic fatigue syndrome/myalgic encephalomyelitis. J Health Psychol.
Edwards R, Suresh R, Lynch S, et al. (2001). Illness perceptions and mood in chronic fatigue syndrome. J Psychosom Res.
Edwards RH, Gibson H, Clague JE, et al. (1993). Muscle histopathology and physiology in chronic fatigue syndrome. Ciba Found Symp.
Eglinton R, Chung MC. (2011). The relationship between posttraumatic stress disorder, illness cognitions, defence styles, fatigue severity and psychological well-being in chronic fatigue syndrome. Psychiatry Res.
Elfaitouri A, Shao X, Mattsson Ulfstedt J, et al. (2011). Murine gammaretrovirus group G3 was not found in Swedish patients with myalgic encephalomyelitis/chronic fatigue syndrome and fibromyalgia. PLoS ONE.
Elliot DL, Goldberg L, Loveless MO. (1997). Graded exercise testing and chronic fatigue syndrome. Am J Med.
Endicott NA. (1999). Chronic fatigue syndrome in private practice psychiatry: family history of physical and mental health. J Psychosom Res.
Enlander D. (2014). RE: ‘Treatment outcome in adults with chronic fatigue syndrome: a prospective study. QJM.
Ernst E. (2004). Letter to the Editor: Comment. J Psychosom Res.
Ernst E. (2004). A randomised, controlled, triple-blind trial of the efficacy of homeopathic treatment for chronic fatigue syndrome. J Psychosom Res.
EuroQol Group. (1990). EuroQol--a new facility for the measurement of health-related quality of life. Health Policy.
Evengard B, Jonzon E, Sandberg A, et al. (2003). Differences between patients with chronic fatigue syndrome and with chronic fatigue at an infectious disease clinic in Stockholm, Sweden. Psychiatry Clin Neurosci.
Evengard B, Nilsson CG, Lindh G, et al. (1998). Chronic fatigue syndrome differs from fibromyalgia. No evidence for elevated substance P levels in cerebrospinal fluid of patients with chronic fatigue syndrome. Pain.
Evering RMH, van Weering MGH, Groothuis-Oudshoorn KCGM, et al. (2011). Daily physical activity of patients with the chronic fatigue syndrome: a systematic review. Clin Rehabil.
Farmer A, Chubb H, Jones I, et al. (1996). Screening for psychiatric morbidity in subjects presenting with chronic fatigue syndrome. Br J Psychiatry.
Farmer A, Jones I, Hillier J, et al. (1995). Neuraesthenia revisited: ICD-10 and DSM-III-R psychiatric syndromes in chronic fatigue patients and comparison subjects. Br J Psychiatry.
Farquhar WB, Hunt BE, Taylor JA, et al. (2002). Blood volume and its relation to peak O(2) consumption and physical activity in patients with chronic fatigue. Am J Physiol Heart Circ Physiol.
Faulkner S, Smith A. (2008). A longitudinal study of the relationship between psychological distress and recurrence of upper respiratory tract infections in chronic fatigue syndrome. Br J Health Psychol.
Feehan SM, Liverpool MESG. (2011). The PACE trial in chronic fatigue syndrome. Lancet.
Ferrans CE, Powers MJ. (1992). Psychometric assessment of the Quality of Life Index. Res Nurs Health.
Ferrans CE, Powers MJ. (1985). Quality of life index: development and psychometric properties. ANS Adv Nurs Sci.
Ferreira AC, de Marchena E. (2002). Grading autonomic dysfunction in chronic fatigue syndrome. Semin Arthritis Rheum.
Field TM, Sunshine W, Hernandez-Reif M, et al. (1997). Massage therapy effects on depression and somatic symptoms in chronic fatigue syndrome. J Chronic Fatigue Syndr.
Fink P, Schroder A. (2010). One single diagnosis, bodily distress syndrome, succeeded to capture 10 diagnostic categories of functional somatic syndromes and somatoform disorders. J Psychosom Res.
Fischler B, Cluydts R, De Gucht Y, et al. (1997). Generalized anxiety disorder in chronic fatigue syndrome. Acta Psychiatr Scand.
Fischler B, Flamen P, Everaert H, et al. (1998). Physiopathological significance of 99mTc HMPAO SPECT scan anomalies in chronic fatigue syndrome: A replication study. J Chronic Fatigue Syndr.
Fisk JD, Ritvo PG, Ross L, et al. (1994). Measuring the functional impact of fatigue: initial validation of the fatigue impact scale. Clin Infect Dis.
Fjorback LO, Arendt M, Ornbol E, et al. (2013). Mindfulness therapy for somatization disorder and functional somatic syndromes: randomized trial with one-year follow-up. J Psychosom Res.
Fjorback LO, Carstensen T, Arendt M, et al. (2013). Mindfulness therapy for somatization disorder and functional somatic syndromes: analysis of economic consequences alongside a randomized trial. J Psychosom Res.
Fletcher MA, Rosenthal M, Antoni M, et al. (2010). Plasma neuropeptide Y: a biomarker for symptom severity in chronic fatigue syndrome. Behav Brain Funct.
Flor-Henry P, Lind JC, Koles ZJ. (2010). EEG source analysis of chronic fatigue syndrome. Psychiatry Res.
Fluge O, Bruland O, Risa K, et al. (2011). Benefit from B-lymphocyte depletion using the anti-CD20 antibody rituximab in chronic fatigue syndrome. A double-blind and placebo-controlled study. PLoS ONE.
Folks TM, Heneine W, Khan A, et al. (1993). Investigation of retroviral involvement in chronic fatigue syndrome. Ciba Found Symp.
Fossey M, Libman E, Bailes S, et al. (2004). Sleep quality and psychological adjustment in chronic fatigue syndrome. J Behav Med.
Freeman R, Komaroff AL. (1997). Does the chronic fatigue syndrome involve the autonomic nervous system?. Am J Med.
Friedberg F. (1999). A subgroup analysis of cognitive-behavioral treatment studies. J Chronic Fatigue Syndr.
Friedberg F, Bateman L, Bested AC, et al. (2012). ME/CFS: A primer for clinical practitioners.
Friedberg F, Dechene L, McKenzie MJ, et al. (2000). Symptom patterns in long-duration chronic fatigue syndrome. J Psychosom Res.
Friedberg F, Krupp LB. (1994). A comparison of cognitive behavioral treatment for chronic fatigue syndrome and primary depression. Clin Infect Dis.
Friedberg F, Napoli A, Coronel J, et al. (2013). Chronic fatigue self-management in primary care: A randomized trial. Psychosom Med.
Friedberg F, Quick J. (2007). Alexithymia in Chronic Fatigue Syndrome: Associations with Momentary, Recall, and Retrospective Measures of Somatic Complaints and Emotion. Psychosom Med.
Friedman TC, Adesanya A, Poland RE. (1999). “Low-dose hydrocortisone for treatment of chronic fatigue syndrome: A randomized controlled trial”: Comment. JAMA.
Frisch MB. (1994). QOLI: Quality of Life Inventory: Manual and Treatment Guide: NCS Pearson.
Frisch MB, Cornell J, Villanueva M, et al. (1992). Clinical Validation of the Quality of Life Inventory: A Measure of Life Satisfaction for Use in Treatment Planning and Outcome Assessment. Psychological Assessment.
Frith J, Zalewski P, Klawe JJ, et al. (2012). Impaired blood pressure variability in chronic fatigue syndrome--a potential biomarker. QJM.
Fu R, Gartlehner G, Grant M, et al. (2011). Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
Fukuda K, Straus SE, Hickie I, et al. (1994). The chronic fatigue syndrome: a comprehensive approach to its definition and study. International Chronic Fatigue Syndrome Study Group. Ann Intern Med.
Fukuda S, Horiguchi M, Yamaguti K, et al. (2013). Association of monoamine-synthesizing genes with the depression tendency and personality in chronic fatigue syndrome patients. Life Sci.
Furlan AD, Pennick V, Bombardier C, et al. (2009). 2009 updated method guidelines for systematic reviews in the Cochrane Back Review Group. Spine (Phila Pa 1976).
Gaab J, Huster D, Peisen R, et al. (2003). Assessment of cortisol response with low-dose and high-dose ACTH in patients with chronic fatigue syndrome and healthy comparison subjects. Psychosomatics.
Galbraith S, Cameron B, Li H, et al. (2011). Peripheral blood gene expression in postinfective fatigue syndrome following from three different triggering infections. J Infect Dis.
Georgiades E, Behan WMH, Kilduff LP, et al. (2003). Chronic fatigue syndrome: new evidence for a central fatigue disorder. Clin Sci.
Geraghty J. (2002). Homeopathic treatment of Chronic Fatigue Syndrome: three case studies using Jan Scholten’s methodology. Homeopathy.
Gharibzadeh S, Hoseini SS. (2006). The potential role of nitric oxide metabolites in diagnosing chronic fatigue syndrome. Med Hypotheses.
Ghosh AK, Ghosh K. (2003). The head-up tilt test for diagnosing chronic fatigue syndrome. QJM.
Giakoumakis J. (2011). The PACE trial in chronic fatigue syndrome. Lancet.
Gibson I. DrIan Gibson’s witness statement in support of the Judicial Review case of the NICE “CFS/ME” Guideline (CG53) online brought by ME patients: Re: Douglas Fraser & Kevin Short v NICE Case Number: CO/10408/2007.
Gibson I, Taylor R, Cryer A, et al. (2006). Inquiry into the status of status of CFS/M.E. and research into causes and treatment Group on Scientific Research into Myalgic into Myalgic Myalgic Encephalomyelitis Encephalomyelitis (ME).
Gibson-Saxty J. (2002). Group therapy for chronic fatigue syndrome. National Research Register.
Gillespie NA, Zhu G, Heath AC, et al. (2000). The genetic aetiology of somatic distress. Psychol Med.
Gladwell PW, Pheby D, Rodriguez T, et al. (2014). Use of an online survey to explore positive and negative outcomes of rehabilitation for people with CFS/ME. Disabil Rehabil.
Godfrey E, Chalder T, Ridsdale L, et al. (2007). Investigating the active ingredients of cognitive behaviour therapy and counselling for patients with chronic fatigue in primary care: developing a new process measure to assess treatment fidelity and predict outcome. Br J Clin Psychol.
Goedendorp MM, van der Werf SP, Bleijenberg G, et al. (2013). Does neuropsychological test performance predict outcome of cognitive behavior therapy for chronic fatigue syndrome and what is the role of underperformance?. J Psychosom Res.
Gold D, Bowden R, Sixbey J, et al. (1990). Chronic fatigue. A prospective clinical and virologic study. JAMA.
Golden HE. (1995). Clinical laboratory test findings in patients with chronic fatigue syndrome. Arch Intern Med.
Goodnick PJ. (1990). Bupropion in chronic fatigue syndrome. Am J Psychiatry.
Goodnick PJ. (1996). Treatment of chronic fatigue syndrome with venlafaxine. Am J Psychiatry.
Goodnick PJ, Jorge CM. (1999). Treatment of chronic fatigue syndrome with nefazodone. Am J Psychiatry.
Goudsmit E. (1998). Treating chronic fatigue with exercise. Exercise, and rest, should be tailored to individual needs. BMJ.
Goudsmit E, Howes S. (2008). Pacing: A strategy to improve energy management in chronic fatigue syndrome. Health Psychology Update.
Goudsmit E, Stouten B, Howes S. (2008). Fatigue in Myalgic Encephalomyelitis. Bulletin of the IACFS/ME.
Gow JW, Behan WM, Clements GB, et al. (1991). Enteroviral RNA sequences detected by polymerase chain reaction in muscle of patients with postviral fatigue syndrome. BMJ.
Gracious B, Wisner KL. (1991). Nortriptyline in chronic fatigue syndrome: a double blind, placebo-controlled single case study. Biol Psychiatry.
Grans H, Nilsson P, Evengard B. (2005). Gene expression profiling in the chronic fatigue syndrome. J Intern Med.
Greco A, Tannock C, Brostoff J, et al. (1997). Brain MR in chronic fatigue syndrome. AJNR Am J Neuroradiol.
Gregg VH. (1997). Hypnosis in chronic fatigue syndrome. J R Soc Med.
Gresham GE, Phillips TF, Labi ML. (1980). ADL status in stroke: relative merits of three standard indexes. Arch Phys Med Rehabil.
Grieco A, Long CJ. (1984). Investigation of the Karnofsky Performance Status as a measure of quality of life. Health Psychol.
Guise J, Widdicombe S, McKinlay A. (2007). ‘What is it like to have ME?’: the discursive construction of ME in computer-mediated communication and face-to-face interaction. Health.
Guo J. (2007). Chronic fatigue syndrome treated by acupuncture and moxibustion in combination with psychological approaches in 310 cases. J Tradit Chin Med.
Gurbaxani BM, Jones JF, Goertzel BN, et al. (2006). Linear data mining the Wichita clinical matrix suggests sleep and allostatic load involvement in chronic fatigue syndrome. Pharmacogenomics.
Guy W. (1976). ECDEU assessment manual for psychopharmacology.
Hall GH, Hamilton WT, Round AP. (1998). Increased illness experience preceding chronic fatigue syndrome: a case control study. J R Coll Physicians Lond.
Hamilton W. (2001). Chronic fatigue syndrome. Br J Gen Pract.
Hamilton WT, Gallagher AM, Thomas JM, et al. (2005). The prognosis of different fatigue diagnostic labels: a longitudinal survey. Fam Pract.
Hamilton WT, Gallagher AM, Thomas JM, et al. (2009). Risk markers for both chronic fatigue and irritable bowel syndromes: a prospective case-control study in primary care. Psychol Med.
Handa KK, Sra JS, Akhtar M. (1997). Successful treatment of a patient with chronic fatigue using head-up tilt guided therapy. Wis Med J.
Hannestad U, Theodorsson E, Evengard B. (2007). beta-Alanine and gamma-aminobutyric acid in chronic fatigue syndrome. Clin Chim Acta.
Hansen AL, Kvale G, Stubhaug B, et al. (2013). Heart rate variability and fatigue in patients with chronic fatigue syndrome after a comprehensive cognitive behavior group therapy program. J Psychophysiol.
Hanson SJ, Gause W, Natelson B. (2001). Detection of immunologically significant factors for chronic fatigue syndrome using neural-network classifiers. Clin Diagn Lab Immunol.
Hard K, Rickards HE, Haque MS, et al. (2009). Pharmacological treatments for chronic fatigue syndrome in adults. Cochrane Database Syst Rev.
Hardcastle SL, Brenu E, Wong N, et al. (2014). 74: Serum cytokines in patients with moderate and severe Chronic Fatigue Syndrome/Myalgic Encephalomyelitis (CFS/ME). Cytokine.
Harmon DL, McMaster D, McCluskey DR, et al. (1997). A common genetic variant affecting folate metabolism is not over-represented in chronic fatigue syndrome. Ann Clin Biochem.
Hartz AJ, Bentler SE, Brake KA, et al. (2003). The effectiveness of citalopram for idiopathic chronic fatigue. J Clin Psychiatry.
Hartz AJ, Kuhn EM, Bentler SE, et al. (1999). Prognostic factors for persons with idiopathic chronic fatigue. Arch Fam Med.
Harvey SB, Wadsworth M, Wessely S, et al. (2008). Etiology of chronic fatigue syndrome: testing popular hypotheses using a national birth cohort study. Psychosom Med.
Harvey SB, Wadsworth M, Wessely S, et al. (2008). The relationship between prior psychiatric disorder and chronic fatigue: evidence from a national birth cohort study. Psychol Med.
Hassan IS, Bannister BA, Akbar A, et al. (1998). A study of the immunology of the chronic fatigue syndrome: correlation of immunologic parameters to health dysfunction. Clin Immunol Immunopathol.
Hatcher S, House A. (2003). Life events, difficulties and dilemmas in the onset of chronic fatigue syndrome: a case-control study. Psychol Med.
Hawk C, Jason LA, Pena J. (2007). Variables that differentiate chronic fatigue syndrome from depression. J Hum Behav Soc Environ.
Hawk C, Jason LA, Torres-Harding S. (2006). Differential diagnosis of chronic fatigue syndrome and major depressive disorder. Int J Behav Med.
Hawk C, Jason LA, Torres-Harding S. (2007). Reliability of a chronic fatigue syndrome questionnaire. J Chronic Fatigue Syndr.
Hayes, Inc. (2013). Chronic fatigue syndrome, diagnosis (Structured abstract). Health Technology Assessment Database.
Hayes, Inc. (2013). Chronic fatigue syndrome, treatment (Structured abstract). Health Technology Assessment Database.
Healthcare Insurance Board/College Voor Z. (2013). Cognitive behavioral therapy for patients with the chronic fatigue syndrome - primary research (Structured abstract). Health Technology Assessment Database.
Heap LC, Peters TJ, Wessely S. (1999). Vitamin B status in patients with chronic fatigue syndrome. J R Soc Med.
Heim C, Wagner D, Maloney E, et al. (2006). Early adverse experience and risk for chronic fatigue syndrome: results from a population-based study. Arch Gen Psychiatry.
Heins M, Knoop H, Nijs J, et al. (2013). Influence of symptom expectancies on stair-climbing performance in chronic fatigue syndrome: Effect of study context. Int J Behav Med.
Heins MJ, Knoop H, Burk WJ, et al. (2013). The process of cognitive behaviour therapy for chronic fatigue syndrome: Which changes in perpetuating cognitions and behaviour are related to a reduction in fatigue?. J Psychosom Res.
Heins MJ, Knoop H, Lobbestael J, et al. (2011). Childhood maltreatment and the response to cognitive behavior therapy for chronic fatigue syndrome. J Psychosom Res.
Heins MJ, Knoop H, Prins JB, et al. (2010). Possible detrimental effects of cognitive behaviour therapy for chronic fatigue syndrome. Psychother Psychosom.
Hellinger WC, Smith TF, Van Scoy RE, et al. (1988). Chronic fatigue syndrome and the diagnostic utility of antibody to Epstein-Barr virus early antigen. JAMA.
Hempel S, Chambers D, Bagnall AM, et al. (2008). Risk factors for chronic fatigue syndrome/myalgic encephalomyelitis: a systematic scoping review of multiple predictor studies. Psychol Med.
Henningsen P, Zimmermann T, Sattel H. (2003). Medically unexplained physical symptoms, anxiety, and depression: a meta-analytic review. Psychosom Med.
Herrell R, Goldberg J, Hartman S, et al. (2002). Chronic fatigue and chronic fatigue syndrome: a co-twin control study of functional status. Qual Life Res.
Hickie I, Davenport T, Wakefield D, et al. (2006). Post-infective and chronic fatigue syndromes precipitated by viral and non-viral pathogens: prospective cohort study. BMJ.
Hickie I, Kirk K, Martin N. (1999). Unique genetic and environmental determinants of prolonged fatigue: a twin study. Psychol Med.
Hickie I, Lloyd A, Wakefield D, et al. (1990). The psychiatric status of patients with the chronic fatigue syndrome. Br J Psychiatry.
Hickie IB, Bansal AS, Kirk KM, et al. (2001). A twin study of the etiology of prolonged fatigue and immune activation. Twin Res.
Hickie IB, Davenport TA, Hadzi-Pavlovic D, et al. (2001). Development of a simple screening tool for common mental disorders in general practice. Med J Aust.
Hickie IB, Hooker AW, Hadzi-Pavlovic D, et al. (1996). Fatigue in selected primary care settings: sociodemographic and psychiatric correlates. Med J Aust.
Hickie IB, Wilson AJ, Wright JM, et al. (2000). A randomized, double-blind placebo-controlled trial of moclobemide in patients with chronic fatigue syndrome. J Clin Psychiatry.
Higgins JP, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
Hill NF, Tiersky LA, Scavalla VR, et al. (1999). Natural history of severe chronic fatigue syndrome. Arch Phys Med Rehabil.
Hinds G, Bell NP, McMaster D, et al. (1994). Normal red cell magnesium concentrations and magnesium loading tests in patients with chronic fatigue syndrome. Ann Clin Biochem.
Hoad A, Spickett G, Elliott J, et al. (2008). Postural orthostatic tachycardia syndrome is an under-recognized condition in chronic fatigue syndrome. QJM.
Hollingsworth KG, Hodgson T, Macgowan GA, et al. (2012). Impaired cardiac function in chronic fatigue syndrome measured using magnetic resonance cardiac tagging. J Intern Med.
Hollingsworth KG, Jones DEJ, Taylor R, et al. (2010). Impaired cardiovascular response to standing in chronic fatigue syndrome. Eur J Clin Invest.
Holmes GP, Kaplan JE, Gantz NM, et al. (1988). Chronic fatigue syndrome: a working case definition. Ann Intern Med.
Hoseini SS, Gharibzadeh S. (2006). Anakinra: a potential treatment for chronic fatigue syndrome. Med Hypotheses.
Ho-Yen DO. (1996). Cognitive behaviour therapy for the chronic fatigue syndrome. Patients’ beliefs about their illness were probably not a major factor. BMJ.
Huber S, Schramm C. (2006). TGF-beta and CD4+CD25+ regulatory T cells. Front Biosci.
Hui J-S. (2009). Acupuncture treatment of chronic fatigue syndrome. J Tradit Chin Med.
Huibers MJ, Wessely S. (2006). The act of diagnosis: pros and cons of labelling chronic fatigue syndrome. Psychol Med.
Huibers MJH, Beurskens AJHM, Van Schayck CP, et al. (2004). Efficacy of cognitive-behavioural therapy by general practitioners for unexplained fatigue among employees: Randomised controlled trial. Br J Psychiatry.
Huibers MJH, Bleijenberg G, van Amelsvoort LGPM, et al. (2004). Predictors of outcome in fatigued employees on sick leave: results from a randomised trial. J Psychosom Res.
Huibers MJH, Bultmann U, Kasl SV, et al. (2004). Predicting the two-year course of unexplained fatigue and the onset of long-term sickness absence in fatigued employees: results from the Maastricht Cohort Study. J Occup Environ Med.
Huibers MJH, Kant IJ, Knottnerus JA, et al. (2004). Development of the chronic fatigue syndrome in severely fatigued employees: predictors of outcome in the Maastricht cohort study. J Epidemiol Community Health.
Huibers MJH, Kant IJ, Swaen GMH, et al. (2004). Prevalence of chronic fatigue syndrome-like caseness in the working population: results from the Maastricht cohort study. Occup Environ Med.
Huibers MJH, Leone SS, Kant IJ, et al. (2006). Chronic fatigue syndrome-like caseness as a predictor of work status in fatigued employees on sick leave: four year follow up study. Occup Environ Med.
Hunskar GS, Langeland N, Wensaas K-A, et al. (2012). The impact of atopic disease on the risk of post-infectious fatigue and irritable bowel syndrome 3 years after Giardia infection. A historic cohort study. Scand J Gastroenterol.
Hunt SM, McKenna SP, McEwen J, et al. (1980). A quantitative approach to perceived health status: a validation study. J Epidemiol Community Health.
Hurel SJ, Abuiasha B, Baylis PH, et al. (1995). Patients with a self diagnosis of myalgic encephalomyelitis. BMJ.
Hurwitz BE, Coryell VT, Parker M, et al. (2010). Chronic fatigue syndrome: illness severity, sedentary lifestyle, blood volume and evidence of diminished cardiac function. Clin Sci.
Hutchinson CV, Badham SP. (2013). Patterns of abnormal visual attention in myalgic encephalomyelitis. Optom Vis Sci.
Hutchinson CV, Maltby J, Badham SP, et al. (2014). Vision-related symptoms as a clinical feature of chronic fatigue syndrome/myalgic encephalomyelitis? Evidence from the DePaul Symptom Questionnaire. Br J Ophthalmol.
Hyland ME, Sodergren SC, Lewith GT. (2006). Chronic fatigue syndrome: the role of positivity to illness in chronic fatigue syndrome patients. J Health Psychol.
Ilaria RL, Komaroff AL, Fagioli LR, et al. (1995). Absence of parvovirus B19 infection in chronic fatigue syndrome. Arthritis Rheum.
Inbar O, Dlin R, Rotstein A, et al. (2001). Physiological responses to incremental exercise in patients with chronic fatigue syndrome. Med Sci Sports Exerc.
Iwakami E, Arashima Y, Kato K, et al. (2005). Treatment of chronic fatigue syndrome with antibiotics: pilot study assessing the involvement of Coxiella burnetii infection. Intern Med.
Jackson C The general health questionnaire Occup Med 2007 57 1 79-Exclusion code: 2 16733255
Jammes Y, Steinberg JG, Delliaux S. (2012). Chronic fatigue syndrome: acute infection and history of physical activity affect resting levels and response to exercise of plasma oxidant/antioxidant status and heat shock proteins. J Intern Med.
Jammes Y, Steinberg JG, Delliaux S, et al. (2009). Chronic fatigue syndrome combines increased exercise-induced oxidative stress and reduced cytokine and Hsp responses. J Intern Med.
Jammes Y, Steinberg JG, Mambrini O, et al. (2005). Chronic fatigue syndrome: assessment of increased oxidative stress and altered muscle excitability in response to incremental exercise. J Intern Med.
Jason L, Evans M, Porter N, et al. (2010). The Development of a Revised Canadian Myalgic Encephalomyelitis Chronic Fatigue Syndrome Case Definition. Am J Biochem Biotechnol.
Jason L, Muldowney K, Torres-Harding S. (2008). The Energy Envelope Theory and myalgic encephalomyelitis/chronic fatigue syndrome. Aaohn J.
Jason L, Najar N, Porter N, et al. (2008). Evaluating the centers for Disease Control’s Empirical Chronic Fatigue Syndrome Case Definition. Journal of Disability policy Studies.
Jason LA, Damrongvachiraphan D, Hunnell J, et al. (2012). Myalgic encephalomyelitis case definitions. Automatic Control Physiol State Funct.
Jason LA, Holbert C, Torres-Harding S, et al. (2004). Stigma and the Term Chronic Fatigue Syndrome: Results of Surveys on Changing the Name. Journal of Disability Policy Studies.
Jason LA, King CP, Richman JA, et al. (1999). U. S. case definition of chronic fatigue syndrome: Diagnostic and theoretical issues. J Chronic Fatigue Syndr.
Jason LA, Melrose H, Lerman A, et al. (1999). Managing chronic fatigue syndrome: overview and case study. Aaohn J.
Jason LA, Porter N, Hunnell J, et al. (2011). A natural history study of chronic fatigue syndrome. Rehabil Psychol.
Jason LA, Richman JA. (2008). How science can stigmatize: The case of chronic fatigue syndrome. J Chronic Fatigue Syndr.
Jason LA, Ropacki MT, Santoro NB, et al. (1997). A screening instrument for chronic fatigue syndrome: Reliability and validity. J Chronic Fatigue Syndr.
Jason LA, Sunnquist M, Brown A, et al. (2014). Examining case definition criteria for chronic fatigue syndrome and myalgic encephalomyeliitis. Fatigue.
Jason LA, Taylor RR. (2002). Applying cluster analysis to define a typology of chronic fatigue syndrome in a medically-evaluated, random community sample. Psychol Health.
Jason LA, Taylor RR, Kennedy CL, et al. (2001). Subtypes of chronic fatigue syndrome: A review of findings. J Chronic Fatigue Syndr.
Jason LA, Taylor RR, Kennedy CL, et al. (2002). A factor analysis of chronic fatigue symptoms in a community-based sample. Soc Psychiatry Psychiatr Epidemiol.
Jason LA, Taylor RR, Kennedy CL, et al. (2000). Chronic fatigue syndrome: occupation, medical utilization, and subtypes in a community-based sample. J Nerv Ment Dis.
Jason LA, Torres-Harding S, Maher K, et al. (2008). Baseline cortisol levels predict treatment outcomes in chronic fatigue syndrome nonpharmacologic clinical trial. J Chronic Fatigue Syndr.
Jason LA, Wagner L, Rosenthal S, et al. (1998). Estimating the prevalence of chronic fatigue syndrome among nurses. Am J Med.
Johnson SK, DeLuca J, Natelson BH. (1996). Assessing somatization disorder in the chronic fatigue syndrome. Psychosom Med.
Johnson SK, Lange G, Tiersky L, et al. (2001). Health-related personality variables in chronic fatigue syndrome and multiple sclerosis. J Chronic Fatigue Syndr.
Johnson SK, Schmaling KB, Dmochowski J, et al. (2010). An investigation of victimization and the clinical course of chronic fatigue syndrome. J Health Psychol.
Johnston S, Brenu E, Staines D, et al. (2014). The role of clinical guidelines for chronic fatigue syndrome/myalgic encephalomyelitis in research settings. Fatigue.
Johnston S, Brenu EW, Staines D, et al. (2013). The prevalence of chronic fatigue syndrome/myalgic encephalomyelitis: a meta-analysis. Clin Epidemiol.
Jones DEJ, Gray J, Frith J, et al. (2011). Fatigue severity remains stable over time and independently associated with orthostatic symptoms in chronic fatigue syndrome: a longitudinal study. J Intern Med.
Jones DEJ, Gray JC, Newton J. (2009). Perceived fatigue is comparable between different disease groups. QJM.
Jones DEJ, Hollingsworth KG, Jakovljevic DG, et al. (2012). Loss of capacity to recover from acidosis on repeat exercise in chronic fatigue syndrome: a case-control study. Eur J Clin Invest.
Jones JF, Maloney EM, Boneva RS, et al. (2007). Complementary and alternative medical therapy utilization by people with chronic fatiguing illnesses in the United States. BMC Altern Med.
Jones JF, Nicholson A, Nisenbaum R, et al. (2005). Orthostatic instability in a population-based study of chronic fatigue syndrome. Am J Med.
Jones JF, Williams M, Schooley RT, et al. (1988). Antibodies to Epstein-Barr virus-specific DNase and DNA polymerase in the chronic fatigue syndrome. Arch Intern Med.
Jones MG, Cooper E, Amjad S, et al. (2005). Urinary and plasma organic acids and amino acids in chronic fatigue syndrome. Clin Chim Acta.
Jones MG, Goodwin CS, Amjad S, et al. (2005). Plasma and urinary carnitine and acylcarnitines in chronic fatigue syndrome. Clin Chim Acta.
Joyce E, Blumenthal S, Wessely S. (1996). Memory, attention, and executive function in chronic fatigue syndrome. J Neurol Neurosurg Psychiatry.
Joyce J, Hotopf M, Wessely S. (1997). The prognosis of chronic fatigue and chronic fatigue syndrome: a systematic review. QJM.
Joyce J, Rabe-Hesketh S, Wessely S. (1998). Reviewing the reviews: the example of chronic fatigue syndrome. JAMA.
Kadikar A, Maurer J, Kesten S. (1997). The six-minute walk test: a guide to assessment for lung transplantation. The Journal of heart and lung transplantation: the official publication of the International Society for Heart Transplantation.
Kakumanu SS, Mende CN, Lehman EB, et al. (2003). Effect of topical nasal corticosteroids on patients with chronic fatigue syndrome and rhinitis. J Am Osteopath Assoc.
Karnofsky DA, Abelmann WH, Craver LF, et al. (1948). The use of the nitrogen mustards in the palliative treatment of carcinoma. With particular reference to bronchogenic carcinoma. Cancer.
Karper WB, Stasik SC. (2003). A successful, long-term exercise program for women with fibromyalgia syndrome and chronic fatigue and immune dysfunction syndrome. Clin Nurse Spec.
Kaslow JE, Rucker L, Onishi R. (1989). Liver extract-folic acid-cyanocobalamin vs placebo for chronic fatigue syndrome. Arch Intern Med.
Kato K, Sullivan PF, Evengard B, et al. (2009). A population-based twin study of functional somatic syndromes. Psychol Med.
Kato K, Sullivan PF, Evengard B, et al. (2006). Premorbid predictors of chronic fatigue. Arch Gen Psychiatry.
Kato K, Sullivan PF, Pedersen NL. (2010). Latent class analysis of functional somatic symptoms in a population-based sample of twins. J Psychosom Res.
Keller BA, Pryor JL, Giloteaux L. (2014). Inability of myalgic encephalomyelitis/chronic fatigue syndrome patients to reproduce VO(2)peak indicates functional impairment. J Transl Med.
Kempke S, Goossens L, Luyten P, et al. (2010). Predictors of outcome in a multi-component treatment program for chronic fatigue syndrome. J Affect Disord.
Kempke S, Van Houdenhove B, Luyten P, et al. (2011). Unraveling the role of perfectionism in chronic fatigue syndrome: is there a distinction between adaptive and maladaptive perfectionism?. Psychiatry Res.
Kennedy G, Spence VA, McLaren M, et al. (2005). Oxidative stress levels are raised in chronic fatigue syndrome and are associated with clinical symptoms. Free Radic Biol Med.
Kerr JR, Bracewell J, Laing I, et al. (2002). Chronic fatigue syndrome and arthralgia following parvovirus B19 infection. J Rheumatol.
Kerr JR, Gough J, Richards SCM, et al. (2010). Antibody to parvovirus B19 nonstructural protein is associated with chronic arthralgia in patients with chronic fatigue syndrome/myalgic encephalomyelitis. J Gen Virol.
Kerr JR, Petty R, Burke B, et al. (2008). Gene expression subtypes in patients with chronic fatigue syndrome/myalgic encephalomyelitis. J Infect Dis.
Kewley AJ. (2011). The PACE trial in chronic fatigue syndrome. Lancet.
Khan AS, Heneine WM, Chapman LE, et al. (1993). Assessment of a retrovirus sequence and other possible risk factors for the chronic fatigue syndrome in adults. Ann Intern Med.
Khan F, Kennedy G, Spence VA, et al. (2004). Peripheral cholinergic function in humans with chronic fatigue syndrome, Gulf War syndrome and with illness following organophosphate exposure. Clin Sci.
Kim J-E, Hong K-E, Kim H-J, et al. (2013). An open-label study of effects of acupuncture on chronic fatigue syndrome and idiopathic chronic fatigue: study protocol for a randomized controlled trial. Trials.
Kim K-W, Chung W-S, Song M-Y, et al. (2013). Complementary and alternative medicine treatments in the management of chronic fatigue syndrome: a systematic review of randomized controlled trials. Orient Pharm Exp Med.
Kindlon T. (2010). Criteria used to define chronic fatigue syndrome questioned. Psychosom Med.
Kindlon T. (2011). Harms of cognitive behaviour therapy designed to increase activity levels in chronic fatigue syndrome: questions remain. Psychother Psychosom.
Kindlon T. (2011). Reporting of Harms Associated with Graded Exercise Therapy and Cognitive Behavioural Therapy in Myalgic Encephalomyelitis/Chronic Fatigue Syndrome. Bull IACFS ME.
Kindlon T. (2009). Response to: exercise performance and chronic pain in chronic fatigue syndrome: the role of pain catastrophizing. Pain Med.
Kishi A, Struzik ZR, Natelson BH, et al. (2008). Dynamics of sleep stage transitions in healthy humans and patients with chronic fatigue syndrome. Am J Physiol Regul Integr Comp Physiol.
Klasnja A, Grujic N, Popadic Gacesa J, et al. (2014). Influence of graded exercise therapy on anxiety levels and health-related quality of life in chronic fatigue syndrome. J Sports Med Phys Fitness.
Knoop H, Heins M, Bloot L, et al. (2013). A treatment model for cognitive-behavioural interventions for chronic fatigue syndrome: Work in progress. J Psychosom Res.
Knoop H, Prins JB, Stulemeijer M, et al. (2007). The effect of cognitive behaviour therapy for chronic fatigue syndrome on self-reported cognitive impairments and neuropsychological test performance. J Neurol Neurosurg Psychiatry.
Knoop H, Stulemeijer M, Prins JB, et al. (2007). Is cognitive behaviour therapy for chronic fatigue syndrome also effective for pain symptoms?. Behav Res Ther.
Komaroff AL, Cho TA. (2011). Role of infection and neurologic dysfunction in chronic fatigue syndrome. Semin Neurol.
Kop WJ, Lyden A, Berlin AA, et al. (2005). Ambulatory monitoring of physical activity and symptoms in fibromyalgia and chronic fatigue syndrome. Arthritis Rheum.
Kreijkamp-Kaspers S, Brenu EW, Marshall S, et al. (2011). Treating chronic fatigue syndrome - a study into the scientific evidence for pharmacological treatments. Aust Fam Physician.
Krilov LR, Fisher M, Friedman SB, et al. (1998). Course and outcome of chronic fatigue in children and adolescents. Pediatrics.
Krotz D. (1998). MR spectroscopy and SPECT capture chronic fatigue. Diagn Imaging (San Franc).
Krupp LB, LaRocca NG, Muir-Nash J, et al. (1989). The fatigue severity scale. Application to patients with multiple sclerosis and systemic lupus erythematosus. Arch Neurol.
Krystal A. (2009). Behavioral insomnia therapy with Chronic Fatigue Syndrome [NCT00540254]. ClinicalTrialsgov.
Kurek JN. (2001). Treatment of chronic fatigue syndrome with methylphenidate. Dissertation Abstracts International.
Kurup RK, Kurup PA. (2003). Hypothalamic digoxin, cerebral chemical dominance and myalgic encephalomyelitis. Int J Neurosci.
LaManca JJ, Sisto SA, DeLuca J, et al. (1998). Influence of exhaustive treadmill exercise on cognitive functioning in chronic fatigue syndrome. Am J Med.
Landay AL, Jessop C, Lennette ET, et al. (1991). Chronic fatigue syndrome: clinical condition associated with immune activation. Lancet.
Lane RJ. (1999). A randomised, placebo controlled study to assess safety and efficacy of galantamine hydrobromide in chronic fatigue syndrome. National Research Register.
Lange G, DeLuca J, Maldjian JA, et al. (1999). Brain MRI abnormalities exist in a subset of patients with chronic fatigue syndrome. J Neurol Sci.
Lapp CW, Hyman HL. (1997). Diagnosis of chronic fatigue syndrome. Arch Intern Med.
Larun L, Brurberg KG, Fonhus MS, et al. (2013). Treatment of chronic fatigue syndrome CFS/ME (Structured abstract). Health Technology Assessment Database.
Larun L, Malterud K. (2007). Identity and coping experiences in Chronic Fatigue Syndrome: a synthesis of qualitative studies. Patient Educ Couns.
Lassesen KM. (2001). Cognitive behaviour therapy for chronic fatigue syndrome. Lancet.
Lavietes MH, Sanchez CW, Tiersky LA, et al. (2000). Psychological profile and ventilatory response to inspiratory resistive loading. Am J Respir Crit Care Med.
Lawrie SM, MacHale SM. (1994). Chronic fatigue syndrome. Lancet.
Le Bon O, Minner P, Van Moorsel C, et al. (2003). First-night effect in the chronic fatigue syndrome. Psychiatry Res.
Le Bon O, Neu D, Berquin Y, et al. (2012). Ultra-slow delta power in chronic fatigue syndrome. Psychiatry Res.
Lee E, Cho S, Kim K, et al. (2009). An integrated approach to infer causal associations among gene expression, genotype variation, and disease. Genomics.
Lee R, Rodin G, Devins G, et al. (2001). Illness experience, meaning and help-seeking among Chinese immigrants in Canada with chronic fatigue and weakness. Anthropol Med.
Lerner AM, Ariza ME, Williams M, et al. (2012). Antibody to Epstein-Barr virus deoxyuridine triphosphate nucleotidohydrolase and deoxyribonucleotide polymerase in a chronic fatigue syndrome subset. PLoS ONE.
Lerner AM, Beqaj SH, Deeter RG, et al. (2002). A six-month trial of valacyclovir in the Epstein-Barr virus subset of chronic fatigue syndrome: improvement in left ventricular function. Drugs Today.
Lerner AM, Beqaj SH, Deeter RG, et al. (2004). IgM serum antibodies to Epstein-Barr virus are uniquely present in a subset of patients with the chronic fatigue syndrome. In Vivo.
Lerner AM, Beqaj SH, Deeter RG, et al. (2007). Valacyclovir treatment in Epstein-Barr virus subset chronic fatigue syndrome: thirty-six months follow-up. In Vivo.
Lerner AM, Lawrie C, Dworkin HS. (1993). Repetitively negative changing T waves at 24-h electrocardiographic monitors in patients with the chronic fatigue syndrome. Left ventricular dysfunction in a cohort. Chest.
Lerner AM, Zervos M, Chang CH, et al. (2001). A small, randomized, placebo-controlled trial of the use of antiviral therapy for patients with chronic fatigue syndrome. Clin Infect Dis.
Lewis DH, Mayberg HS, Fischer ME, et al. (2001). Monozygotic twins discordant for chronic fatigue syndrome: regional cerebral blood flow SPECT. Radiology.
Lewis I, Pairman J, Spickett G, et al. (2013). Clinical characteristics of a novel subgroup of chronic fatigue syndrome patients with postural orthostatic tachycardia syndrome. J Intern Med.
Libman E, Creti L, Baltzan M, et al. (2009). Sleep apnea and psychological functioning in chronic fatigue syndrome. J Health Psychol.
Lieberman J, Bell DS. (1993). Serum angiotensin-converting enzyme as a marker for the chronic fatigue-immune dysfunction syndrome: a comparison to serum angiotensin-converting enzyme in sarcoidosis. Am J Med.
Light AR, Bateman L, Jo D, et al. (2012). Gene expression alterations at baseline and following moderate exercise in patients with Chronic Fatigue Syndrome and Fibromyalgia Syndrome. J Intern Med.
Lijue Z. (2005). Acupuncture and Chinese patent drugs for treatment of chronic fatigue syndrome. J Tradit Chin Med.
Lin JM, Brimmer DJ, Maloney EM, et al. (2009). Further validation of the Multidimensional Fatigue Inventory in a US adult population sample. Popul Health Metr.
Lindh G, Samuelson A, Hedlund KO, et al. (1996). No findings of enteroviruses in Swedish patients with chronic fatigue syndrome. Scand J Infect Dis.
Lipkin DP, Scriven AJ, Crake T, et al. (1986). Six minute walking test for assessing exercise capacity in chronic heart failure. Br Med J (Clin Res Ed).
Liu Z, Wang D, Xue Q, et al. (2003). Determination of fatty acid levels in erythrocyte membranes of patients with chronic fatigue syndrome. Nutr Neurosci.
Lloyd A, Hanna DA, Wakefield D. (1988). Interferon and myalgic encephalomyelitis. Lancet.
Lloyd A, Hickie I, Brockman A, et al. (1991). Cytokine levels in serum and cerebrospinal fluid in patients with chronic fatigue syndrome and control subjects. J Infect Dis.
Lloyd A, Hickie I, Brockman A, et al. (1994). A Controlled Trial of Immunologic and Cognitive-Behavioral Therapy for Patients with Chronic Fatigue Syndrome. Clin Infect Dis.
Lloyd A, Hickie I, Wakefield D, et al. (1990). A double-blind, placebo-controlled trial of intravenous immunoglobulin therapy in patients with chronic fatigue syndrome. Am J Med.
Lloyd AR. (2004). To exercise or not to exercise in chronic fatigue syndrome? No longer a question. Med J Aust.
Lloyd AR, Gandevia SC, Hales JP. (1991). Muscle performance, voluntary activation, twitch properties and perceived effort in normal subjects and patients with the chronic fatigue syndrome. Brain.
Lloyd AR, Hickie I, Boughton CR, et al. (1990). Prevalence of chronic fatigue syndrome in an Australian population. Med J Aust.
Lloyd AR, Hickie I, Brockman A, et al. (1993). Immunologic and psychologic therapy for patients with chronic fatigue syndrome: a double-blind, placebo-controlled trial. Am J Med.
Lloyd AR, Wakefield D, Boughton CR, et al. (1989). Immunological abnormalities in the chronic fatigue syndrome. Med J Aust.
Lo S-C, Pripuzova N, Li B, et al. (2010). Detection of MLV-related virus gene sequences in blood of patients with chronic fatigue syndrome and healthy blood donors. Proc Natl Acad Sci U S A.
Lo S-C, Pripuzova N, Li B, et al. (2012). Retraction for Lo et al., Detection of MLV-related virus gene sequences in blood of patients with chronic fatigue syndrome and healthy blood donors. Proc Natl Acad Sci U S A.
Lombardi VC, Ruscetti FW, Das Gupta J, et al. (2009). Detection of an infectious retrovirus, XMRV, in blood cells of patients with chronic fatigue syndrome. Science.
Lorig K, Chastain RL, Ung E, et al. (1989). Development and evaluation of a scale to measure perceived self-efficacy in people with arthritis. Arthritis Rheum.
Lowe MM, Mold JE, Kanwar B, et al. (2014). Identification of cinnabarinic acid as a novel endogenous aryl hydrocarbon receptor ligand that drives IL-22 production. PLoS ONE.
Lowry TJ, Pakenham KI. (2008). Health-related quality of life in chronic fatigue syndrome: predictors of physical functioning and psychological distress. Psychol Health Med.
Luyten P, Van Houdenhove B, Pae CU, et al. (2008). Treatment of chronic fatigue syndrome: findings, principles and strategies. Psychiatry Investig.
Lynch S, Fraser J. (1998). “Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome”: Commentary. Br J Psychiatry.
MacDonald KL, Osterholm MT, LeDell KH, et al. (1996). A case-control study to assess possible triggers and cofactors in chronic fatigue syndrome. Am J Med.
MacHale S, Lawrie S, Cavanagh J, et al. (2000). “Cerebral perfusion in chronic fatigue syndrome and depression”: Reply. Br J Psychiatry.
MacHale SM, Cavanagh JT, Bennie J, et al. (1998). Diurnal variation of adrenocortical activity in chronic fatigue syndrome. Neuropsychobiology.
MacHale SM, Lawrie SM, Cavanagh JT, et al. (2000). Cerebral perfusion in chronic fatigue syndrome and depression. Br J Psychiatry.
Maes M, Anderson G, Morris G, et al. (2013). Diagnosis of myalgic encephalomyelitis: where are we now?. Expert Opin Med Diagn.
Maes M, Leunis J-C. (2008). Normalization of leaky gut in chronic fatigue syndrome (CFS) is accompanied by a clinical improvement: effects of age, duration of illness and the translocation of LPS from gram-negative bacteria. Neuroendocrinol Lett.
Maes M, Mihaylova I, De Ruyter M. (2006). Lower serum zinc in Chronic Fatigue Syndrome (CFS): relationships to immune dysfunctions and relevance for the oxidative stress status in CFS. J Affect Disord.
Maes M, Mihaylova I, Kubera M, et al. (2009). Coenzyme Q10 deficiency in myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS) is related to fatigue, autonomic and neurocognitive symptoms and is another risk factor explaining the early mortality in ME/CFS due to cardiovascular disorder. Neuroendocrinol Lett.
Maes M, Mihaylova I, Kubera M, et al. (2009). Increased 8-hydroxy-deoxyguanosine, a marker of oxidative damage to DNA, in major depression and myalgic encephalomyelitis/chronic fatigue syndrome. Neuroendocrinol Lett.
Maes M, Mihaylova I, Kubera M, et al. (2011). Lower whole blood glutathione peroxidase (GPX) activity in depression, but not in myalgic encephalomyelitis/chronic fatigue syndrome: another pathway that may be associated with coronary artery disease and neuroprogression in depression. Neuroendocrinol Lett.
Maes M, Mihaylova I, Leunis J-C. (2007). Increased serum IgA and IgM against LPS of enterobacteria in chronic fatigue syndrome (CFS): indication for the involvement of gram-negative enterobacteria in the etiology of CFS and for the presence of an increased gut-intestinal permeability. J Affect Disord.
Maes M, Ringel K, Kubera M, et al. (2013). In myalgic encephalomyelitis/chronic fatigue syndrome, increased autoimmune activity against 5-HT is associated with immuno-inflammatory pathways and bacterial translocation. J Affect Disord.
Maes M, Twisk FNM, Kubera M, et al. (2012). Evidence for inflammation and activation of cell-mediated immunity in Myalgic Encephalomyelitis/Chronic Fatigue Syndrome (ME/CFS): increased interleukin-1, tumor necrosis factor-, PMN-elastase, lysozyme and neopterin. J Affect Disord.
Maes M, Twisk FNM, Kubera M, et al. (2012). Increased IgA responses to the LPS of commensal bacteria is associated with inflammation and activation of cell-mediated immunity in chronic fatigue syndrome. J Affect Disord.
Maher KJ, Klimas NG, Fletcher MA. (2005). Chronic fatigue syndrome is associated with diminished intracellular perforin. Clin Exp Immunol.
Mahoney FI, Barthel DW. (1965). Functional Evaluation: The Barthel Index. Md State Med J.
Main CJ. (1983). The Modified Somatic Perception Questionnaire (MSPQ). J Psychosom Res.
Main J. (2000). A phase II randomised placebo controlled study to assess the safety and efficacy of galantamine hydrobromide 25mg tid and 10mg tid taken for a period of 16 wks in patients with a diagnosis of chronic fatigue syndrome (MREC). National Research Register.
Majer M, Welberg LAM, Capuron L, et al. (2008). Neuropsychological performance in persons with chronic fatigue syndrome: results from a population-based study. Psychosom Med.
Maloney EM, Boneva R, Nater UM, et al. (2009). Chronic fatigue syndrome and high allostatic load: results from a population-based case-control study in Georgia. Psychosom Med.
Maloney EM, Gurbaxani BM, Jones JF, et al. (2006). Chronic fatigue syndrome and high allostatic load. Pharmacogenomics.
Malouff JM, Thorsteinsson EB, Rooke SE, et al. (2008). Efficacy of cognitive behavioral therapy for chronic fatigue syndrome: a meta-analysis. Clin Psychol Rev.
Mantysaari M. (1991). Aerobic work capacity in chronic fatigue syndrome. BMJ.
Manu P, Lane TJ, Matthews DA. (1988). The frequency of the chronic fatigue syndrome in patients with symptoms of persistent fatigue. Ann Intern Med.
Manu P, Lane TJ, Matthews DA. (1996). Idiopathic chronic fatigue: Depressive symptoms and functional somatic complaints. Chronic fatigue syndrome: An integrative approach to evaluation and treatment.
Maquet D, Demoulin C, Crielaard JM. (2006). Chronic fatigue syndrome: a systematic review. Ann Readapt Med Phys.
Mariman A, Delesie L, Tobback E, et al. (2013). Undiagnosed and comorbid disorders in patients with presumed chronic fatigue syndrome. J Psychosom Res.
Mariman A, Vogelaers D, Hanoulle I, et al. (2012). Subjective sleep quality and daytime sleepiness in a large sample of patients with chronic fatigue syndrome (CFS). Acta Clin Belg.
Marlin RG, Anchel H, Gibson JC, et al. (1998). An evaluation of multidisciplinary intervention for chronic fatigue syndrome with long-term follow-up, and a comparison with untreated controls. Am J Med.
Marques M, De Gucht V, Maes S, et al. (2012). Protocol for the “four steps to control your fatigue (4-STEPS)” randomised controlled trial: a self-regulation based physical activity intervention for patients with unexplained chronic fatigue. BMC Public Health.
Martin RWY, Ogston SA, Evans JR. (1994). Effects of vitamin and mineral supplementation on symptoms associated with chronic fatigue syndrome with Coxsackie B antibodies. J Nutr Med.
Masuda A, Nakayama T, Yamanaka T, et al. (2001). Cognitive behavioral therapy and fasting therapy for a patient with chronic fatigue syndrome. Intern Med.
Matthews RM, Komaroff AL. (2007). Changes in functional status in chronic fatigue syndrome over a decade: Do age and gender matter?. J Chronic Fatigue Syndr.
Mawle AC, Nisenbaum R, Dobbins JG, et al. (1997). Immune responses associated with chronic fatigue syndrome: a case-control study. J Infect Dis.
Mawle AC, Nisenbaum R, Dobbins JG, et al. (1995). Seroepidemiology of chronic fatigue syndrome: a case-control study. Clin Infect Dis.
McArdle A, McArdle F, Jackson MJ, et al. (1996). Investigation by polymerase chain reaction of enteroviral infection in patients with chronic fatigue syndrome. Clin Sci.
McCluskey DR. (1993). Pharmacological approaches to the therapy of chronic fatigue syndrome. Ciba Found Symp.
McCrone P, Ridsdale L, Darbishire L, et al. (2004). Cost-effectiveness of cognitive behavioural therapy, graded exercise and usual care for patients with chronic fatigue in primary care. Psychol Med.
McCrone P, Sharpe M, Chalder T, et al. (2012). Adaptive pacing, cognitive behaviour therapy, graded exercise, and specialist medical care for chronic fatigue syndrome: a cost-effectiveness analysis. PLoS ONE.
McCue P, Buchanan T, Martin CR. (2006). Screening for psychological distress using internet administration of the Hospital Anxiety and Depression Scale (HADS) in individuals with chronic fatigue syndrome. Br J Clin Psychol.
McCully KK, Natelson BH. (1999). Impaired oxygen delivery to muscle in chronic fatigue syndrome. Clin Sci.
McCully KK, Smith S, Rajaei S, et al. (2003). Blood flow and muscle metabolism in chronic fatigue syndrome. Clin Sci.
McCully KK, Smith S, Rajaei S, et al. (2004). Muscle metabolism with blood flow restriction in chronic fatigue syndrome. J Appl Physiol.
McDermott C, Richards SCM, Thomas PW, et al. (2006). A placebo-controlled, double-blind, randomized controlled trial of a natural killer cell stimulant (BioBran MGN-3) in chronic fatigue syndrome. QJM.
McDonald E, David AS, Pelosi AJ, et al. (1993). Chronic fatigue in primary care attenders. Psychol Med.
McGarry F, Gow J, Behan PO. (1994). Enterovirus in the chronic fatigue syndrome. Ann Intern Med.
McKendrick M. (1999). Chronic fatigue syndrome: a controlled trial of the efficacy of homoeopathic treatment. National Research Register.
McLaughlin B. (1991). Virology laboratory diagnosis of chronic fatigue syndrome. Can Dis Wkly Rep.
McNair, Lorr, Droppelman. (1971). Manual: Profile of Mood States.
Meeus M, Nijs J, Meirleir KD. (2007). Chronic musculoskeletal pain in patients with the chronic fatigue syndrome: a systematic review. Eur J Pain.
Meeus M, Nijs J, Van de Wauwer N, et al. (2008). Diffuse noxious inhibitory control is delayed in chronic fatigue syndrome: an experimental study. Pain.
Meeus M, Nijs J, Van Oosterwijck J, et al. (2010). Pain physiology education improves pain beliefs in patients with chronic fatigue syndrome compared with pacing and self-management education: a double-blind randomized controlled trial. Arch Phys Med Rehabil.
Meeus M, van Eupen I, van Baarle E, et al. (2011). Symptom fluctuations and daily physical activity in patients with chronic fatigue syndrome: a case-control study. Arch Phys Med Rehabil.
Michael A. (1998). Treating chronic fatigue with exercise. Exercise improves mood and sleep. BMJ.
Michiels V, Cluydts R. (2001). Neuropsychological functioning in chronic fatigue syndrome: a review. Acta Psychiatr Scand.
Mildon CA. (1991). Clinical observations of chronic fatigue syndrome. Can Dis Wkly Rep.
Miller NA, Carmichael HA, Calder BD, et al. (1991). Antibody to Coxsackie B virus in diagnosing postviral fatigue syndrome. BMJ.
Mitchell AJ. (2000). A phase II randomised, placebo-controlled study to assess the safety and efficacy of galantamine hydrobromide 25mg TID, 5mg TID, 75mg TID and 10mg TID taken for a period of 16 weeks in patients with a diagnosis of chronic fatigue syndrome (CFS). National Research Register.
Mitchell JT. (2011). The PACE trial in chronic fatigue syndrome. Lancet.
Miwa K, Fujita M. (2009). Cardiac function fluctuates during exacerbation and remission in young adults with chronic fatigue syndrome and “small heart”. J Cardiol.
Miwa K, Fujita M. (2010). Fluctuation of serum vitamin E (alpha-tocopherol) concentrations during exacerbation and remission phases in patients with chronic fatigue syndrome. Heart Vessels.
Miwa K, Fujita M. (2009). Increased oxidative stress suggested by low serum vitamin E concentrations in patients with chronic fatigue syndrome. Int J Cardiol.
Mizoguchi A. (2012). Healing of intestinal inflammation by IL-22. Inflamm Bowel Dis.
Montague TJ, Marrie TJ, Klassen GA, et al. (1989). Cardiac function at rest and with exercise in the chronic fatigue syndrome. Chest.
Moore RA, Straube S, Paine J, et al. (2010). Fibromyalgia: Moderate and substantial pain intensity reduction predicts improvement in other outcomes and substantial quality of life gain. Pain.
Moorkens G, Wynants H, Abs R. (1998). Effect of growth hormone treatment in patients with chronic fatigue syndrome: a preliminary study. Growth Horm IGF Res.
Morgan RM, Parry AMM, Arida RM, et al. (2007). Effects of elevated plasma tryptophan on brain activation associated with the Stroop task. Psychopharmacology.
Morris G, Anderson G, Galecki P, et al. (2013). A narrative review on the similarities and dissimilarities between myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS) and sickness behavior. BMC Med.
Morriss R. (2014). Chronic fatigue syndrome/myalgic encephalomyelitis: more heat, some light--directions for research and clinical practice. J Neurol Neurosurg Psychiatry.
Morriss RK, Robson MJ, Deakin JFW. (2002). Neuropsychological performance and noradrenaline function in chronic fatigue syndrome under conditions of high arousal. Psychopharmacology.
Morriss RK, Wearden AJ. (1998). Screening instruments for psychiatric morbidity in chronic fatigue syndrome. J R Soc Med.
Morriss RK, Wearden AJ, Mullis R. (1998). Exploring the validity of the Chalder Fatigue scale in chronic fatigue syndrome. J Psychosom Res.
Morte S, Castilla A, Civeira MP, et al. (1988). Gamma-interferon and chronic fatigue syndrome. Lancet.
Moss-Morris R, Petrie KJ. (1997). Cognitive distortions of somatic experiences: revision and validation of a measure. J Psychosom Res.
Moss-Morris R, Petrie KJ. (2003). Experimental evidence for interpretive but not attention biases towards somatic information in patients with chronic fatigue syndrome. Br J Health Psychol.
Moss-Morris R, Spence MJ, Hou R. (2011). The pathway from glandular fever to chronic fatigue syndrome: can the cognitive behavioural model provide the map?. Psychol Med.
Muir P, Nicholson F, Banatvala JE, et al. (1991). Coxsackie B virus and postviral fatigue syndrome. BMJ.
Mulrow CD, Ramirez G, Cornell JE, et al. (2001). Defining and managing chronic fatigue syndrome. Evid Rep Technol Assess (Summ).
Mundt JC, Marks IM, Shear MK, et al. (2002). The Work and Social Adjustment Scale: a simple measure of impairment in functioning. Br J Psychiatry.
Murdoch JC. (1988). Cell-mediated immunity in patients with myalgic encephalomyelitis syndrome. N Z Med J.
Myers C, Wilks D. (1999). Comparison of Euroqol EQ-5D and SF-36 in patients with chronic fatigue syndrome. Qual Life Res.
Nacul LC, Lacerda EM, Campion P, et al. (2011). The functional status and well being of people with myalgic encephalomyelitis/chronic fatigue syndrome and their carers. BMC Public Health.
Nacul LC, Lacerda EM, Pheby D, et al. (2011). Prevalence of myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS) in three regions of England: a repeated cross-sectional study in primary care. BMC Med.
Naess H, Sundal E, Myhr K-M, et al. (2010). Postinfectious and chronic fatigue syndromes: clinical experience from a tertiary-referral centre in Norway. In Vivo.
Nagelkirk PR, Cook DB, Peckerman A, et al. (2003). Aerobic capacity of Gulf War veterans with chronic fatigue syndrome. Mil Med.
Nakamura T, Schwander S, Donnelly R, et al. (2013). Exercise and sleep deprivation do not change cytokine expression levels in patients with chronic fatigue syndrome. Clin Vaccine Immunol.
Nakatomi Y, Mizuno K, Ishii A, et al. (2014). Neuroinflammation in Patients with Chronic Fatigue Syndrome/Myalgic Encephalomyelitis: An 11C-(R)-PK11195 PET Study. J Nucl Med.
Nakaya T, Takahashi H, Nakamura Y, et al. (1996). Demonstration of Borna disease virus RNA in peripheral blood mononuclear cells derived from Japanese patients with chronic fatigue syndrome. FEBS Lett.
Narita M, Nishigami N, Narita N, et al. (2003). Association between serotonin transporter gene polymorphism and chronic fatigue syndrome. Biochem Biophys Res Commun.
Nas K, Cevik R, Batum S, et al. (2011). Immunologic and psychosocial status in chronic fatigue syndrome. Bratisl Lek Listy.
Naschitz J, Dreyfuss D, Yeshurun D, et al. (2004). Midodrine treatment for chronic fatigue syndrome. Postgrad Med J.
Naschitz JE, Mussafia-Priselac R, Kovalev Y, et al. (2006). Patterns of hypocapnia on tilt in patients with fibromyalgia, chronic fatigue syndrome, nonspecific dizziness, and neurally mediated syncope. Am J Med Sci.
Naschitz JE, Rosner I, Rozenbaum M, et al. (2004). Patterns of cardiovascular reactivity in disease diagnosis. QJM.
Naschitz JE, Rosner I, Rozenbaum M, et al. (2000). The capnography head-up tilt test for evaluation of chronic fatigue syndrome. Semin Arthritis Rheum.
Naschitz JE, Rosner I, Rozenbaum M, et al. (2003). Successful treatment of chronic fatigue syndrome with midodrine: a pilot study. Clin Exp Rheumatol.
Naschitz JE, Rosner I, Rozenbaum M, et al. (2003). The head-up tilt test with haemodynamic instability score in diagnosing chronic fatigue syndrome. QJM.
Naschitz JE, Rozenbaum M, Fields M, et al. (2005). Search for disease-specific cardiovascular reactivity patterns: developing the methodology. Clin Sci.
Naschitz JE, Sabo E, Dreyfuss D, et al. (2003). The head-up tilt test in the diagnosis and management of chronic fatigue syndrome. Isr Med Assoc J.
Naschitz JE, Sabo E, Naschitz S, et al. (2002). Hemodynamics instability score in chronic fatigue syndrome and in non-chronic fatigue syndrome. Semin Arthritis Rheum.
Naschitz JE, Sabo E, Naschitz S, et al. (2002). Fractal analysis and recurrence quantification analysis of heart rate and pulse transit time for diagnosing chronic fatigue syndrome. Clin Auton Res.
Naschitz JE, Sabo E, Naschitz S, et al. (2001). Hemodynamic instability in chronic fatigue syndrome: indices and diagnostic significance. Semin Arthritis Rheum.
Naschitz JE, Slobodin G, Sharif D, et al. (2008). Electrocardiographic QT interval and cardiovascular reactivity in fibromyalgia differ from chronic fatigue syndrome. Eur J Intern Med.
Natelson BH, Cheu J, Hill N, et al. (1998). Single-blind, placebo phase-in trial of two escalating doses of selegiline in the chronic fatigue syndrome. Neuropsychobiology.
Natelson BH, Cheu J, Pareja J, et al. (1996). Randomized, double blind, controlled placebo-phase in trial of low dose phenelzine in the chronic fatigue syndrome. Psychopharmacology.
Natelson BH, Cohen JM, Brassloff I, et al. (1993). A controlled study of brain magnetic resonance imaging in patients with the chronic fatigue syndrome. J Neurol Sci.
Natelson BH, LaManca JJ, Denny TN, et al. (1998). Immunologic parameters in chronic fatigue syndrome, major depression, and multiple sclerosis. Am J Med.
Natelson BH, Tiersky L, Nelson J. (2001). The diagnosis of posttraumatic stress disorder in Gulf veterans with medically unexplained fatiguing illness. J Nerv Ment Dis.
Natelson BH, Weaver SA, Tseng C-L, et al. (2005). Spinal fluid abnormalities in patients with chronic fatigue syndrome. Clin Diagn Lab Immunol.
Nater UM, Lin J-M, Maloney EM, et al. (2010). “Criteria used to define chronic fatigue syndrome questioned.”: Reply. Psychosom Med.
Nater UM, Maloney E, Boneva RS, et al. (2008). Attenuated morning salivary cortisol concentrations in a population-based study of persons with chronic fatigue syndrome and well controls. J Clin Endocrinol Metab.
Nater UM, Maloney E, Heim C, et al. (2011). Cumulative life stress in chronic fatigue syndrome. Psychiatry Res.
National Horizon Scanning Centre. (2014). Ampligen (poly1:polyC12U) for chronic fatigue syndrome: horizon scanning technology briefing (Project record). Health Technology Assessment Database.
Nawab SS, Miller CS, Dale JK, et al. (2000). Self-reported sensitivity to chemical exposures in five clinical populations and healthy controls. Psychiatry Res.
Neu D, Kajosch H, Peigneux P, et al. (2011). Cognitive impairment in fatigue and sleepiness associated conditions. Psychiatry Res.
Neu D, Linkowski P, Le Bon O. (2010). Clinical complaints of daytime sleepiness and fatigue: How to distinguish and treat them, especially when they become ‘excessive’ or ‘chronic’?. Acta Neurol Belg.
Neu D, Mairesse O, Hoffmann G, et al. (2007). Sleep quality perception in the chronic fatigue syndrome: correlations with sleep efficiency, affective symptoms and intensity of fatigue. Neuropsychobiology.
Newton JL, Okonkwo O, Sutcliffe K, et al. (2007). Symptoms of autonomic dysfunction in chronic fatigue syndrome. QJM.
Newton JL, Pairman J, Hallsworth K, et al. (2011). Physical activity intensity but not sedentary activity is reduced in chronic fatigue syndrome and is associated with autonomic regulation. QJM.
Newton JL, Sheth A, Shin J, et al. (2009). Lower ambulatory blood pressure in chronic fatigue syndrome. Psychosom Med.
Ng S-M, Yiu Y-M. (2013). Acupuncture for chronic fatigue syndrome: a randomized, sham-controlled trial with single-blinded design. Altern Ther Health Med.
Niblett SH, King KE, Dunstan RH, et al. (2007). Hematologic and urinary excretion anomalies in patients with chronic fatigue syndrome. Exp Biol Med.
Nickel JC, Tripp DA, Pontari M, et al. (2010). Interstitial cystitis/painful bladder syndrome and associated medical conditions with an emphasis on irritable bowel syndrome, fibromyalgia and chronic fatigue syndrome. J Urol.
Nicolson GL, Gan R, Haier J. (2003). Multiple co-infections (Mycoplasma, Chlamydia, human herpes virus-6) in blood of chronic fatigue syndrome patients: association with signs and symptoms. Apmis.
Nijrolder I, van der Windt D, de Vries H, et al. (2009). Diagnoses during follow-up of patients presenting with fatigue in primary care. CMAJ.
Nijs J, Adriaens J, Schuermans D, et al. (2008). Breathing retraining in patients with chronic fatigue syndrome: a pilot study. Physiother.
Nijs J, Almond F, De Becker P, et al. (2008). Can exercise limits prevent post-exertional malaise in chronic fatigue syndrome? An uncontrolled clinical trial. Clin Rehabil.
Nijs J, De Becker P, De Meirleir K, et al. (2003). Associations between bronchial hyperresponsiveness and immune cell parameters in patients with chronic fatigue syndrome. Chest.
Nijs J, De Meirleir K. (2004). Prediction of peak oxygen uptake in patients fulfilling the 1994 CDC criteria for chronic fatigue syndrome. Clin Rehabil.
Nijs J, Nees A, Paul L, et al. (2014). Altered immune response to exercise in patients with chronic fatigue syndrome/myalgic encephalomyelitis: a systematic literature review. Exerc Immunol Rev.
Nijs J, Roussel N, Van Oosterwijck J, et al. (2013). Fear of movement and avoidance behaviour toward physical activity in chronic-fatigue syndrome and fibromyalgia: state of the art and implications for clinical practice. Clin Rheumatol.
Nijs J, Van Oosterwijck J, Meeus M, et al. (2010). Unravelling the nature of postexertional malaise in myalgic encephalomyelitis/chronic fatigue syndrome: the role of elastase, complement C4a and interleukin-1beta. J Intern Med.
Nijs J, Vanherberghen K, Duquet W, et al. (2004). Chronic fatigue syndrome: lack of association between pain-related fear of movement and exercise capacity and disability. Phys Ther.
Nijs J, Zwinnen K, Meeusen R, et al. (2007). Comparison of two exercise testing protocols in patients with chronic fatigue syndrome. J Rehabil Res Dev.
Nisenbaum R, Jones A, Jones J, et al. (2000). Longitudinal analysis of symptoms reported by patients with chronic fatigue syndrome. Ann Epidemiol.
Nisenbaum R, Jones JF, Unger ER, et al. (2003). A population-based study of the clinical course of chronic fatigue syndrome. Health Qual Life Outcomes.
Nisenbaum R, Reyes M, Mawle AC, et al. (1998). Factor analysis of unexplained severe fatigue and interrelated symptoms: overlap with criteria for chronic fatigue syndrome. Am J Epidemiol.
Nishikai M, Tomomatsu S, Hankins RW, et al. (2001). Autoantibodies to a 68/48 kDa protein in chronic fatigue syndrome and primary fibromyalgia: a possible marker for hypersomnia and cognitive disorders. Rheumatology (Oxford).
Njoku MGC, Jason LA, Torres-Harding SR. (2005). The relationships among coping styles and fatigue in an ethnically diverse sample. Ethn Health.
Nowotny N, Kolodziejek J. (2000). Demonstration of borna disease virus nucleic acid in a patient with chronic fatigue syndrome. J Infect Dis.
Ocon AJ, Messer ZR, Medow MS, et al. (2012). Increasing orthostatic stress impairs neurocognitive functioning in chronic fatigue syndrome with postural tachycardia syndrome. Clin Sci.
O’Dell MW, Lubeck DP, O’Driscoll P, et al. (1995). Validity of the Karnofsky Performance Status in an HIV-infected sample. J Acquir Immune Defic Syndr Hum Retrovirol.
O’Dowd H. (2000). Cognitive behavioural therapy in chronic fatigue syndrome (CFS): A randomised controlled trial of an outpatient group programme. Current Controlled Trials.
Ohashi K, Bleijenberg G, van der Werf S, et al. (2004). Decreased fractal correlation in diurnal physical activity in chronic fatigue syndrome. Methods Inf Med.
Okamoto LE, Raj SR, Peltier A, et al. (2012). Neurohumoral and haemodynamic profile in postural tachycardia and chronic fatigue syndromes. Clin Sci.
O’Keane V. (1998). The use of sertraline in non-depressed patients suffering from chronic fatigue syndrome (CFS). National Research Register.
Ortega F, Zorzanelli R. (2011). Cien Saude Colet.
Ortega-Hernandez O-D, Cuccia M, Bozzini S, et al. (2009). Autoantibodies, polymorphisms in the serotonin pathway, and human leukocyte antigen class II alleles in chronic fatigue syndrome: are they associated with age at onset and specific symptoms?. Ann N Y Acad Sci.
O’Sullivan SJ. (1992). Alleged link between hepatitis B vaccine and chronic fatigue syndrome. CMAJ.
Pae C-U, Marks DM, Patkar AA, et al. (2009). Pharmacological treatment of chronic fatigue syndrome: focusing on the role of antidepressants. Expert Opin Pharmacother.
Papadopoulos A, Ebrecht M, Roberts ADL, et al. (2009). Glucocorticoid receptor mediated negative feedback in chronic fatigue syndrome using the low dose (0.5 mg) dexamethasone suppression test. J Affect Disord.
Pardaens K, Haagdorens L, Van Wambeke P, et al. (2006). How relevant are exercise capacity measures for evaluating treatment effects in chronic fatigue syndrome? Results from a prospective, multidisciplinary outcome study. Clin Rehabil.
Pardini M, Guida S, Primavera A, et al. (2011). Amisulpride vs. fluoxetine treatment of chronic fatigue syndrome: a pilot study. Eur Neuropsychopharmacol.
Patnaik M, Komaroff AL, Conley E, et al. (1995). Prevalence of IgM antibodies to human herpesvirus 6 early antigen (p41/38) in patients with chronic fatigue syndrome. J Infect Dis.
Paul LM, Wood L, Maclaren W. (2001). The effect of exercise on gait and balance in patients with chronic fatigue syndrome. Gait Posture.
Pennebaker JW. (1982). The psychology of physical symptoms.
Penttila IA, Harris RJ, Storm P, et al. (1998). Cytokine dysregulation in the post-Q-fever fatigue syndrome. QJM.
Pepper CM, Krupp LB, Friedberg F, et al. (1993). A comparison of neuropsychiatric characteristics in chronic fatigue syndrome, multiple sclerosis, and major depression. J Neuropsychiatry Clin Neurosci.
Perrin R, Embleton K, Pentreath VW, et al. (2010). Longitudinal MRI shows no cerebral abnormality in chronic fatigue syndrome. Br J Radiol.
Perrin RN, Edwards J, Hartley P. (1998). An evaluation of the effectiveness of osteopathic treatment on symptoms associated with myalgic encephalomyelitis. A preliminary report. J Med Eng Technol.
Perrins DJ. (1990). The diagnosis of postviral syndrome. J R Soc Med.
Peterson PK, Pheley A, Schroeppel J, et al. (1998). A preliminary placebo-controlled crossover trial of fludrocortisone for chronic fatigue syndrome. Arch Intern Med.
Plioplys AV, Plioplys S. (1997). Amantadine and L-carnitine treatment of Chronic Fatigue Syndrome. Neuropsychobiology.
Poole J, Herrell R, Ashton S, et al. (2000). Results of isoproterenol tilt table testing in monozygotic twins discordant for chronic fatigue syndrome. Arch Intern Med.
Poppe C, Crombez G, Hanoulle I, et al. (2012). Mental quality of life in chronic fatigue is associated with an accommodative coping style and neuroticism: a path analysis. Qual Life Res.
Poppe C, Petrovic M, Vogelaers D, et al. (2013). Cognitive behavior therapy in patients with chronic fatigue syndrome: The role of illness acceptance and neuroticism. J Psychosom Res.
Porter NS, Jason LA, Boulton A, et al. (2010). Alternative medical interventions used in the treatment and management of myalgic encephalomyelitis/chronic fatigue syndrome and fibromyalgia. J Altern Complement Med.
Powell DJ, Liossi C, Moss-Morris R, et al. (2013). Unstimulated cortisol secretory activity in everyday life and its relationship with fatigue and chronic fatigue syndrome: A systematic review and subset meta-analysis. Psychoneuroendocrinology.
Powell P, Bentall RP, Nye FJ, et al. (2001). Randomised controlled trial of patient education to encourage graded exercise in chronic fatigue syndrome. BMJ.
Powell P, Bentall RP, Nye FJ, et al. (2004). Patient education to encourage graded exercise in chronic fatigue syndrome. 2-year follow-up of randomised controlled trial. Br J Psychiatry.
Price JR, Couper J. (2000). Cognitive behaviour therapy for adults with chronic fatigue syndrome. Cochrane Database Syst Rev.
Price JR, Mitchell E, Tidy E, et al. (2008). Cognitive behaviour therapy for chronic fatigue syndrome in adults. Cochrane Database Syst Rev.
Price JR, Mitchell E, Tidy E, et al. (2009). Cognitive behaviour therapy for chronic fatigue syndrome in adults. Cochrane Database Syst Rev.
Prins JB, Bleijenberg G, Bazelmans E, et al. (2001). Cognitive behaviour therapy for chronic fatigue syndrome: a multicentre randomised controlled trial. Lancet.
Puri BK. (2004). The use of eicosapentaenoic acid in the treatment of chronic fatigue syndrome. Prostaglandins Leukot Essent Fatty Acids.
Puri BK, Agour M, Gunatilake KDR, et al. (2009). An in vivo proton neurospectroscopy study of cerebral oxidative stress in myalgic encephalomyelitis (chronic fatigue syndrome). Prostaglandins Leukot Essent Fatty Acids.
Puri BK, Counsell SJ, Zaman R, et al. (2002). Relative increase in choline in the occipital cortex in chronic fatigue syndrome. Acta Psychiatr Scand.
Query M, Taylor RR. (2005). Linkages between goal attainment and quality of life for individuals with chronic fatigue syndrome. Occup Ther Health Care.
Quinn C. (2010). A mystery no more. Nurs Stand.
Racciatti D, Vecchiet J, Ceccomancini A, et al. (2001). Chronic fatigue syndrome following a toxic exposure. Sci Total Environ.
Raine R, Haines A, Sensky T, et al. (2002). Systematic review of mental health interventions for patients with common somatic symptoms: can research evidence from secondary care be extrapolated to primary care?. BMJ.
Raison CL, Lin J-MS, Reeves WC. (2009). Association of peripheral inflammatory markers with chronic fatigue in a population-based sample. Brain Behav Immun.
Ramsay AM, Dowsett EG, Dadswell JV, et al. (1977). Icelandic disease (benign myalgic encephalomyelitis or Royal Free disease). BMJ.
Randall DC, Cafferty FH, Shneerson JM, et al. (2005). Chronic treatment with modafinil may not be beneficial in patients with chronic fatigue syndrome. J Psychopharmacol.
Ranjith G. (2005). Epidemiology of chronic fatigue syndrome. Occup Med (Oxf).
Rao AV, Bested AC, Beaulne TM, et al. (2009). A randomized, double-blind, placebo-controlled pilot study of a probiotic in emotional symptoms of chronic fatigue syndrome. Gut Pathog.
Ravindran MK, Zheng Y, Timbol C, et al. (2011). Migraine headaches in chronic fatigue syndrome (CFS): comparison of two prospective cross-sectional studies. BMC Neurol.
Razumovsky AY, DeBusk K, Calkins H, et al. (2003). Cerebral and systemic hemodynamics changes during upright tilt in chronic fatigue syndrome. J Neuroimaging.
Rea T, Buchwald D. (1999). Hydrocortisone and chronic fatigue syndrome. Lancet.
Reeves WC, Wagner D, Nisenbaum R, et al. (2005). Chronic fatigue syndrome--a clinically empirical approach to its definition and study. BMC Med.
Reid S, Chalder T, Cleare A, et al. (2005). Chronic fatigue syndrome. Clin Evid.
Reuter SE, Evans AM. (2011). Long-chain acylcarnitine deficiency in patients with chronic fatigue syndrome. Potential involvement of altered carnitine palmitoyltransferase-I activity. J Intern Med.
Reviews NHSCf, Dissemination. (2013). The effectiveness of interventions used in the treatment/management of chronic fatigue syndrome and/or myalgic encephalomyelitis in adults and children (Structured abstract). Health Technology Assessment Database.
Reviews NHSCf, Dissemination. (2013). Interventions for the management of CFS/ME (Structured abstract). Health Technology Assessment Database.
Reyes M, Dobbins JG, Nisenbaum R, et al. (1999). Chronic Fatigue Syndrome Progression and Self-Defined Recovery: Evidence from the CDC Surveilance System. J Chronic Fatigue Syndr.
Reynolds GK, Lewis DP, Richardson AM, et al. (2014). Comorbidity of postural orthostatic tachycardia syndrome and chronic fatigue syndrome in an Australian cohort. J Intern Med.
Ridsdale L, Darbishire L, Seed PT. (2004). Is graded exercise better than cognitive behaviour therapy for fatigue? A UK randomized trial in primary care. Psychol Med.
Ridsdale L, Godfrey E, Chalder T, et al. (2001). Chronic fatigue in general practice: is counselling as good as cognitive behaviour therapy? A UK randomised trial. Br J Gen Pract.
Ridsdale L, Hurley M, King M, et al. (2012). The effect of counselling, graded exercise and usual care for people with chronic fatigue in primary care: a randomized trial. Psychol Med.
Rimes KA, Wingrove J. (2013). Mindfulness-based cognitive therapy for people with chronic fatigue syndrome still experiencing excessive fatigue after cognitive behaviour therapy: a pilot randomized study. Clin Psychol Psychother.
Roberts ADL, Charler ML, Papadopoulos A, et al. (2010). Does hypocortisolism predict a poor response to cognitive behavioural therapy in chronic fatigue syndrome?. Psychol Med.
Roberts ADL, Papadopoulos AS, Wessely S, et al. (2009). Salivary cortisol output before and after cognitive behavioural therapy for chronic fatigue syndrome. J Affect Disord.
Roberts ADL, Wessely S, Chalder T, et al. (2004). Salivary cortisol response to awakening in chronic fatigue syndrome. Br J Psychiatry.
Robertson MJ, Schacterle RS, Mackin GA, et al. (2005). Lymphocyte subset differences in patients with chronic fatigue syndrome, multiple sclerosis and major depression. Clin Exp Immunol.
Ross SD, Estok RP, Frame D, et al. (2004). Disability and chronic fatigue syndrome: a focus on function. Arch Intern Med.
Ross SD, Levine C, Ganz N, et al. (2002). Systematic review of the current literature related to disability and chronic fatigue syndrome. Evid Rep Technol Assess (Summ).
Ross SD, Levine C, Ganz N, et al. (2013). Systematic review of the current literature related to disability and chronic fatigue syndrome (Structured abstract). Health Technology Assessment Database.
Rouleau G, Ceppi U, Hjelholt Pedersen V, et al. (2013). Chronic fatigue syndrome: state of the evidence and assessment of intervention modalities in Quebec (Structured abstract). Health Technology Assessment Database.
Rowe PC, Calkins H, DeBusk K, et al. (2001). Fludrocortisone acetate to treat neurally mediated hypotension in chronic fatigue syndrome: a randomized controlled trial. JAMA.
Rowe PC, Lucas KE. (2007). Orthostatic intolerance in chronic fatigue syndrome. Am J Med.
Roy-Byrne P, Afari N, Ashton S, et al. (2002). Chronic fatigue and anxiety/depression: a twin study. Br J Psychiatry.
Russell V, Atkinson C, Lewin B, et al. A group rehabilitation approach to chronic fatigue syndrome. 29th Annual Conference of the British Association for Behavioural and Cognitive Psychotherapies.
Russo J, Katon W, Clark M, et al. (1998). Longitudinal changes associated with improvement in chronic fatigue patients. J Psychosom Res.
Sabath DE, Barcy S, Koelle DM, et al. (2002). Cellular immunity in monozygotic twins discordant for chronic fatigue syndrome. J Infect Dis.
Sabes-Figuera R, McCrone P, Hurley M, et al. (2012). Cost-effectiveness of counselling, graded-exercise and usual care for chronic fatigue: evidence from a randomised trial in primary care. BMC Health Serv Res.
Sacco P, Hope PA, Thickbroom GW, et al. (1999). Corticomotor excitability and perception of effort during sustained exercise in the chronic fatigue syndrome. Clin Neurophysiol.
Sadlier M, Evans JR, Phillips C, et al. (2000). A preliminary study into the effectiveness of multi-convergent therapy in the treatment of heterogeneous patients with chronic fatigue syndrome. J Chronic Fatigue Syndr.
Saez-Francas N, Alegre J, Calvo N, et al. (2012). Attention-deficit hyperactivity disorder in chronic fatigue syndrome patients. Psychiatry Res.
Saggini R, Pizzigallo E, Vecchiet J, et al. (1998). Alteration of spatial-temporal parameters of gait in Chronic Fatigue Syndrome patients. J Neurol Sci.
Saggini R, Vecchiet J, Iezzi S, et al. (2006). Submaximal aerobic exercise with mechanical vibrations improves the functional status of patients with chronic fatigue syndrome. Eur.
Saiki T, Kawai T, Morita K, et al. (2008). Identification of marker genes for differential diagnosis of chronic fatigue syndrome. Mol Med.
Sakudo A, Kuratsune H, Kobayashi T, et al. (2006). Spectroscopic diagnosis of chronic fatigue syndrome by visible and near-infrared spectroscopy in serum samples. Biochem Biophys Res Commun.
Salyers MP, Bosworth HB, Swanson JW, et al. (2000). Reliability and validity of the SF-12 health survey among people with severe mental illness. Med Care.
Santaella ML, Font I, Disdier OM. (2004). Comparison of oral nicotinamide adenine dinucleotide (NADH) versus conventional therapy for chronic fatigue syndrome. P R Health Sci J.
Sathyapalan T, Beckett S, Rigby AS, et al. (2010). High cocoa polyphenol rich chocolate may reduce the burden of the symptoms in chronic fatigue syndrome. Nutr J.
Saxty M, Hansen Z. (2005). Group Cognitive Behavioural Therapy for Chronic Fatigue Syndrome: A Pilot Study. Behav Cogn Psychother.
Scadding JG. (1967). Diagnosis: the clinician and the computer. Lancet.
Scheeres K, Wensing M, Bleijenberg G, et al. (2008). Implementing cognitive behavior therapy for chronic fatigue syndrome in mental health care: a costs and outcomes analysis. BMC Health Serv Res.
Schikler KN. (2006). Potential polygenic influences on chronic fatigue syndrome. Pediatrics.
Schillings ML, Kalkman JS, van der Werf SP, et al. (2004). Diminished central activation during maximal voluntary contraction in chronic fatigue syndrome. Clin Neurophysiol.
Schmaling KB, DiClementi JD, Cullum CM, et al. (1994). Cognitive functioning in chronic fatigue syndrome and depression: a preliminary comparison. Psychosom Med.
Schmaling KB, Fiedelak JI, Bader J, et al. (2005). A longitudinal study of physical activity and body mass index among persons with unexplained chronic fatigue. J Psychosom Res.
Schmaling KB, Fiedelak JI, Katon WJ, et al. (2003). Prospective study of the prognosis of unexplained chronic fatigue in a clinic-based cohort. Psychosom Med.
Schmaling KB, Smith WR, Buchwald DS. (2000). Significant other responses are associated with fatigue and functional status among patients with chronic fatigue syndrome. Psychosom Med.
Schmidley JW, Hines J. (1994). Folate and chronic fatigue syndrome. Neurology.
Schmitz N, Hartkamp N, Kiuse J, et al. (2000). The Symptom Check-List-90-R (SCL-90-R): a German validation study. Qual Life Res.
Schondorf R, Benoit J, Wein T, et al. (1999). Orthostatic intolerance in the chronic fatigue syndrome. J Auton Nerv Syst.
Schreurs KMG, Veehof MM, Passade L, et al. (2011). Cognitive behavioural treatment for chronic fatigue syndrome in a rehabilitation setting: effectiveness and predictors of outcome. Behav Res Ther.
Schrezenmaier C, Gehrking JA, Hines SM, et al. (2005). Evaluation of orthostatic hypotension: relationship of a new self-report instrument to laboratory-based measures. Mayo Clin Proc.
Schrijvers D, Van Den Eede F, Maas Y, et al. (2009). Psychomotor functioning in chronic fatigue syndrome and major depressive disorder: a comparative study. J Affect Disord.
Scott LV, Burnett F, Medbak S, et al. (1998). Naloxone-mediated activation of the hypothalamic-pituitary-adrenal axis in chronic fatigue syndrome. Psychol Med.
Scott LV, Medbak S, Dinan TG. (1998). Blunted adrenocorticotropin and cortisol responses to corticotropin-releasing hormone stimulation in chronic fatigue syndrome. Acta Psychiatr Scand.
Scott LV, Svec F, Dinan T. (2000). A preliminary study of dehydroepiandrosterone response to low-dose ACTH in chronic fatigue syndrome and in healthy subjects. Psychiatry Res.
Scroop GC, Burnet RB. (2004). To exercise or not to exercise in chronic fatigue syndrome?. Med J Aust.
See DM, Broumand N, Sahl L, et al. (1997). In vitro effects of echinacea and ginseng on natural killer and antibody-dependent cell cytotoxicity in healthy subjects and chronic fatigue syndrome or acquired immunodeficiency syndrome patients. Immunopharmacology.
See DM, Tilles JG. (1996). alpha-Interferon treatment of patients with chronic fatigue syndrome. Immunol Invest.
Selden SM, Cameron AS. (1996). Changing epidemiology of Ross River virus disease in South Australia. Med J Aust.
Sendrowski DP, Buker EA, Gee SS. (1997). An investigation of sympathetic hypersensitivity in chronic fatigue syndrome. Optom Vis Sci.
Severens JL, Prins JB, van der Wilt GJ, et al. (2004). Cost-effectiveness of cognitive behaviour therapy for patients with chronic fatigue syndrome. QJM.
Shanks MF, Ho-Yen DO. (1995). A clinical study of chronic fatigue syndrome. Br J Psychiatry.
Sharma A, Kendall MJ, Oyebode F, et al. (1996). Fluoxetine and chronic fatigue syndrome. Lancet.
Sharma A, Oyebode F, Kendall MJ, et al. (2001). Recovery from chronic fatigue syndrome associated with changes in neuroendocrine function. J R Soc Med.
Sharpe M. (1993). Non-pharmacological approaches to treatment. Ciba Found Symp.
Sharpe MC, Archard LC, Banatvala JE, et al. (1991). A report--chronic fatigue syndrome: guidelines for research. J R Soc Med.
Shea BJ, Hamel C, Wells GA, et al. (2009). AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol.
Shepherd C. (1991). Intravenous immunoglobulin and myalgic encephalomyelitis. BMJ.
Shepherd C, Macintyre A. (1997). Graded exercise in chronic fatigue syndrome. Patients should have initial period of rest before gradual increase in activity. BMJ.
Sheridan A. Raw data for 6mwt, Freedom of Information request to Queen Mary, University of London.
Shin H-Y, An N-H, Cha Y-J, et al. (2004). Effect of Kuibitang on lipopolysaccharide-induced cytokine production in peripheral blood mononuclear cells of chronic fatigue syndrome patients. J Ethnopharmacol.
Shinohara M. (2011). The PACE trial in chronic fatigue syndrome. Lancet.
Shishioh-Ikejima N, Ogawa T, Yamaguti K, et al. (2010). The increase of alpha-melanocyte-stimulating hormone in the plasma of chronic fatigue syndrome patients. BMC Neurol.
Siegel SD, Antoni MH, Fletcher MA, et al. (2006). Impaired natural immunity, cognitive dysfunction, and physical symptoms in patients with chronic fatigue syndrome: preliminary evidence for a subgroup?. J Psychosom Res.
Siemionow V, Fang Y, Calabrese L, et al. (2004). Altered central nervous system signal during motor performance in chronic fatigue syndrome. Clin Neurophysiol.
Siessmeier T, Nix WA, Hardt J, et al. (2003). Observer independent analysis of cerebral glucose metabolism in patients with chronic fatigue syndrome. J Neurol Neurosurg Psychiatry.
Simpson LO. (1990). Are ME and chronic fatigue syndrome the same disease?. N Z Med J.
Simpson LO. (1999). ME versus CFS. N Z Med J.
Simpson LO. (1995). Myalgic encephalomyelitis and chronic fatigue syndrome. N Z Med J.
Simpson LO. (1989). Nondiscocytic erythrocytes in myalgic encephalomyelitis. N Z Med J.
Sirois DA, Natelson B. (2001). Clinicopathological findings consistent with primary Sjogren’s syndrome in a subset of patients diagnosed with chronic fatigue syndrome: preliminary observations. J Rheumatol.
Sisto SA, LaManca J, Cordero DL, et al. (1996). Metabolic and cardiovascular effects of a progressive exercise test in patients with chronic fatigue syndrome. Am J Med.
Sisto SA, Tapp WN, LaManca JJ, et al. (1998). Physical activity before and after exercise in women with chronic fatigue syndrome. QJM.
Skapinakis P, Lewis G, Mavreas V. (2004). Temporal relations between unexplained fatigue and depression: longitudinal data from an international study in primary care. Psychosom Med.
Skapinakis P, Lewis G, Mavreas V. (2003). Unexplained fatigue syndromes in a multinational primary care sample: specificity of definition and prevalence and distinctiveness from depression and generalized anxiety. Am J Psychiatry.
Skapinakis P, Lewis G, Meltzer H. (2000). Clarifying the relationship between unexplained chronic fatigue and psychiatric morbidity: results from a community survey in Great Britain. Am J Psychiatry.
Skowera A, Cleare A, Blair D, et al. (2004). High levels of type 2 cytokine-producing cells in chronic fatigue syndrome. Clin Exp Immunol.
Skowera A, Stewart E, Davis ET, et al. (2002). Antinuclear autoantibodies (ANA) in Gulf War-related illness and chronic fatigue syndrome (CFS) patients. Clin Exp Immunol.
Smets EM, Garssen B, Bonke B, et al. (1995). The Multidimensional Fatigue Inventory (MFI) psychometric qualities of an instrument to assess fatigue. J Psychosom Res.
Smirnova IV, Pall ML. (2003). Elevated levels of protein carbonyls in sera of chronic fatigue syndrome patients. Mol Cell Biochem.
Smith AK, Fang H, Whistler T, et al. (2011). Convergent genomic studies identify association of GRIK2 and NPAS2 with chronic fatigue syndrome. Neuropsychobiology.
Smith AK, Maloney EM, Falkenberg VR, et al. (2009). An angiotensin-1 converting enzyme polymorphism is associated with allostatic load mediated by C-reactive protein, interleukin-6 and cortisol. Psychoneuroendocrinology.
Smith C, Wessely S. (2014). Unity of opposites? Chronic fatigue syndrome and the challenge of divergent perspectives in guideline development. J Neurol Neurosurg Psychiatry.
Smith MEB, Nelson N, Haney E, et al. (2014). Diagnosis and treatment of myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS). PROSPERO 2014:CRD42014009779.
Smith S, Sullivan K. (2003). Examining the influence of biological and psychological factors on cognitive performance in chronic fatigue syndrome: a randomized, double-blind, placebo-controlled, crossover study. Int J Behav Med.
Smith WR, Strachan ED, Buchwald D. (2009). Coping, self-efficacy and psychiatric history in patients with both chronic widespread pain and chronic fatigue. Gen Hosp Psychiatry.
Smits M, van Rooy R, Nagtegaal J. (2002). Influence of melatonin on quality of life in patients with chronic fatigue and late melatonin onset. J Chronic Fatigue Syndr.
Snell CR, Stevens SR, Davenport TE, et al. (2013). Discriminative validity of metabolic and workload measurements for identifying people with chronic fatigue syndrome. Phys Ther.
Snorrason E, Geirsson A, Stefansson K. (1996). Trial of a selective acetylcholinesterase inhibitor, galanthamine hydrobromide, in the treatment of chronic fatigue syndrome. J Chronic Fatigue Syndr.
Soderberg S, Evengard B. (2001). Short-term group therapy for patients with chronic fatigue syndrome. Psychother Psychosom.
Solomon L, Reeves WC. (2004). Factors influencing the diagnosis of chronic fatigue syndrome. Arch Intern Med.
Song S, Jason LA. (2005). A population-based study of chronic fatigue syndrome (CFS) experienced in differing patient groups: An effort to replicate Vercoulen et al.’s model of CFS. J Ment Health.
Sorensen B, Streib JE, Strand M, et al. (2003). Complement activation in a model of chronic fatigue syndrome. J Allergy Clin Immunol.
Spath M, Welzel D, Farber L. (2000). Treatment of chronic fatigue syndrome with 5-HT3 receptor antagonists--preliminary results. Scand J Rheumatol Suppl.
Spence VA, Kennedy G, Belch JJF, et al. (2008). Low-grade inflammation and arterial wave reflection in patients with chronic fatigue syndrome. Clin Sci.
Spence VA, Khan F, Belch JJ. (2000). Enhanced sensitivity of the peripheral cholinergic vascular response in patients with chronic fatigue syndrome. Am J Med.
Springer RE, Wray BB, Latham JE. (1992). A double blind, placebo controlled study of intravenous gammaglobulin (GG) in the treatment of chronic fatigue syndrome (CFS). Ann Allergy.
Spruit MA, Gosselink R, Decramer M. (2003). High heart rates at anaerobic threshold in healthy women. Arch Intern Med.
Stanley PJ. (2001). Chronic fatigue syndrome: A controlled trial of the efficacy of homeopathic treatment. National Research Register.
Starr A, Scalise A, Gordon R, et al. (2000). Motor cortex excitability in chronic fatigue syndrome. Clin Neurophysiol.
Steer RG. (1992). Echovirus 16 orchitis and postviral fatigue syndrome. Med J Aust.
Steinau M, Unger ER, Vernon SD, et al. (2004). Differential-display PCR of peripheral blood for biomarker discovery in chronic fatigue syndrome. J Mol Med.
Steinberg P, McNutt BE, Marshall P, et al. (1996). Double-blind placebo-controlled study of the efficacy of oral terfenadine in the treatment of chronic fatigue syndrome. J Allergy Clin Immunol.
Steinberg P, Pheley A, Peterson PK. (1996). Influence of immediate hypersensitivity skin reactions on delayed reactions in patients with chronic fatigue syndrome. J Allergy Clin Immunol.
Stewart AL, Greenfield S, Hays RD, et al. (1989). Functional status and well-being of patients with chronic conditions. Results from the Medical Outcomes Study. JAMA.
Stewart AL, Hays RD, Ware JE. (1988). The MOS short-form general health survey. Reliability and validity in a patient population. Med Care.
Stewart JM. (2010). Chronic fatigue syndrome: comments on deconditioning, blood volume and resulting cardiac function. Clin Sci.
Stewart JM, Gewitz MH, Weldon A, et al. (1999). Patterns of orthostatic intolerance: the orthostatic tachycardia syndrome and adolescent chronic fatigue. J Pediatr.
Stewart JM, Medow MS, Messer ZR, et al. (2012). Postural neurocognitive and neuronal activated cerebral blood flow deficits in young chronic fatigue syndrome patients with postural tachycardia syndrome. Am J Physiol Heart Circ Physiol.
Stouch BC, Strayer D, Carter W. (2010). Cardiac toxicity in Chronic Fatigue Syndrome: results from a randomized 40-week multicenter double-blind placebo control trial of rintatolimod. J Appl Res.
Stouten B. (2004). Chronic fatigue syndrome: a clinical and laboratory study with a well-matched control group. J Intern Med.
Strahler J, Fischer S, Nater UM, et al. (2013). Norepinephrine and epinephrine responses to physiological and pharmacological stimulation in chronic fatigue syndrome. Biol Psychol.
Strang JM. (2002). Treatment of chronic fatigue syndrome: A cognitive-behavioral approach to enhance personal mastery. Dissertation Abstracts International.
Straus SE, Dale JK, Peter JB, et al. (1989). Circulating lymphokine levels in the chronic fatigue syndrome. J Infect Dis.
Straus SE, Dale JK, Tobi M, et al. (1988). Acyclovir treatment of the chronic fatigue syndrome. Lack of efficacy in a placebo-controlled trial. N Engl J Med.
Straus SE, Fritz S, Dale JK, et al. (1993). Lymphocyte phenotype and function in the chronic fatigue syndrome. J Clin Immunol.
Straus SE, McKenzie R, Demitrack MA. (1999). “Low-dose hydrocortisone for treatment of chronic fatigue syndrome: A randomized controlled trial”: Reply. JAMA.
Streeten DH, Bell DS. (1999). Long- and short-term blood pressure and RR-interval variability and psychosomatic distress in chronic fatigue syndrome. Clin Sci.
Stubhaug B, Lie SA, Ursin H, et al. (2008). Cognitive-behavioural therapy v. mirtazapine for chronic fatigue and neurasthenia: randomised placebo-controlled trial. Br J Psychiatry.
Subira ML, Castilla A, Civeira MP, et al. (1989). Deficient display of CD3 on lymphocytes of patients with chronic fatigue syndrome. J Infect Dis.
Suhadolnik RJ, Peterson DL, Reichenbach NL, et al. (2004). Clinical and Biochemical Characteristics Differentiating Chronic Fatigue Syndrome from Major Depression and Healthy Control Populations: Relation to Dysfunction in the RNase L Pathway. J Chronic Fatigue Syndr.
Suhadolnik RJ, Reichenbach NL, Hitzges P, et al. (1994). Changes in the 2–5A synthetase/RNase L antiviral pathway in a controlled clinical trial with poly(I)-poly(C12U) in chronic fatigue syndrome. In Vivo.
Suhadolnik RJ, Reichenbach NL, Hitzges PM, et al. (1993). RNA drug therapy acting via the 2–5A synthetase/RNase L pathway. Ann N Y Acad Sci.
Sullivan PF, Allander T, Lysholm F, et al. (2011). An unbiased metagenomic search for infectious agents using monozygotic twins discordant for chronic fatigue. BMC Microbiol.
Sullivan PF, Evengard B, Jacks A, et al. (2005). Twin analyses of chronic fatigue in a Swedish national sample. Psychol Med.
Sullivan PF, Kovalenko P, York TP, et al. (2003). Fatigue in a community sample of twins. Psychol Med.
Sundbom E, Henningsson M, Holm U, et al. (2002). Possible influence of defenses and negative life events on patients with chronic fatigue syndrome: a pilot study. Psychol Rep.
Surawy C, Roberts J, Silver A. (2005). The effect of mindfulness training on mood and measures of fatigue, activity, and quality of life in patients with chronic fatigue syndrome on a hospital waiting list: A series of exploratory studies. Behav Cogn Psychother.
Swanink CM, Vercoulen JH, Bleijenberg G, et al. (1995). Chronic fatigue syndrome: a clinical and laboratory study with a well matched control group. J Intern Med.
Swanink CM, Vercoulen JH, Galama JM, et al. (1996). Lymphocyte subsets, apoptosis, and cytokines in patients with chronic fatigue syndrome. J Infect Dis.
Taylor RR. (2006). Rehabilitation Programs for Individuals with Chronic Fatigue Syndrome: A Review. J Chronic Fatigue Syndr.
Taylor RR, Jason LA, Kennedy CL, et al. (2001). Effect of physician-recommended treatment on mental health practitioners’ attributions for chronic fatigue syndrome. Rehabil Psychol.
Taylor RR, Jason LA, Torres A. (2000). Fatigue rating scales: an empirical comparison. Psychol Med.
Taylor RR, Kielhofner GW. (2005). Work-related impairment and employment-focused rehabilitation options for individuals with chronic fatigue syndrome: A review. J Ment Health.
Teitelbaum J. (2002). Highly effective treatment of fibromyalgia and chronic fatigue syndrome - results of a placebo controlled study and how to apply the protocol. Townsend Letter.
Teitelbaum JE, Bird B, Greenfield RM, et al. (2001). Effective treatment of chronic fatigue syndrome and fibromyalgia - A randomized, double-blind, placebo-controlled, intent-to-treat study. J Chronic Fatigue Syndr.
Teitelbaum JE, Bird B, Weiss A, et al. (1999). Low-dose hydrocortisone for chronic fatigue syndrome. JAMA.
The GKH, Bleijenberg G, Buitelaar JK, et al. (2010). The effect of ondansetron, a 5-HT3 receptor antagonist, in chronic fatigue syndrome: a randomized controlled trial. J Clin Psychiatry.
The Norwegian Knowledge Centre for the Health S. (2013). A review of the scientific literature for diagnosis and treatment of chronic fatigue syndrome/myalgic encephalopathy (CFS/ME) (Structured abstract). Health Technology Assessment Database.
Theoharides TC, Papaliodis D, Tagen M, et al. (2005). Chronic fatigue syndrome, mast cells, and tricyclic antidepressants. J Clin Psychopharmacol.
Thomas M, Sadlier M, Smith A. (2006). The effect of Multi Convergent Therapy on the psychopathology, mood and performance of Chronic Fatigue Syndrome patients: A preliminary study. Counselling and Psychotherapy Research.
Thomas M, Smith A. (2007). An evaluation of counselling and rehabilitation courses for Chronic Fatigue Syndrome. Counselling & Psychotherapy Research.
Thomas MA, Sadlier MJ, Smith AP. (2008). A multiconvergent approach to the rehabilitation of patients with chronic fatigue syndrome: a comparative study. Physiotherapy.
Tiersky LA, DeLuca J, Hill N, et al. (2001). Longitudinal assessment of neuropsychological functioning, psychiatric status, functional disability and employment status in chronic fatigue syndrome. Appl Neuropsychol.
Tiersky LA, Matheis RJ, Deluca J, et al. (2003). Functional status, neuropsychological functioning, and mood in chronic fatigue syndrome (CFS): relationship to psychiatric disorder. J Nerv Ment Dis.
Tiev KP, Briant M, Ziani M, et al. (2005). Variability of the RNase L isoform ratio (37 kiloDaltons/83 kiloDaltons) in diagnosis of chronic fatigue syndrome. Clin Diagn Lab Immunol.
Tiev KP, Cabane J, Imbert JC. (1999). Rev Med Interne.
Timmers HJLM, Wieling W, Soetekouw PMMB, et al. (2002). Hemodynamic and neurohumoral responses to head-up tilt in patients with chronic fatigue syndrome. Clin Auton Res.
Tirelli U, Chierichetti F, Tavio M, et al. (1998). Brain positron emission tomography (PET) in chronic fatigue syndrome: preliminary data. Am J Med.
Tirelli U, Lleshi A, Berretta M, et al. (2013). Treatment of 741 Italian patients with chronic fatigue syndrome. Eur Rev Med Pharmacol Sci.
Tirelli V, Pinto A, Marotta G, et al. (1993). Clinical and immunologic study of 205 patients with chronic fatigue syndrome: a case series from Italy. Arch Intern Med.
Tomoda A, Joudoi T, Rabab E-M, et al. (2005). Cytokine production and modulation: comparison of patients with chronic fatigue syndrome and normal controls. Psychiatry Res.
Toussaint LL, Whipple MO, Abboud LL, et al. (2012). A mind-body technique for symptoms related to fibromyalgia and chronic fatigue. Explore (NY).
Trikalinos T, Balion C. (2012). Chapter 9: Options for Summarizing Medical Test Performance in the Absence of a “Gold Standard”. J Gen Intern Med.
Trikalinos TA, Balion CM. (2012). Options for Summarizing Medical Test Performance in the Absence of a “Gold Standard”.
Tummers M, Lucassen PL, Wiborg JFW, et al. (2013). The challenge of diagnosing CFS in primary care. Int J Clin Pract.
Turnberg L, Caldicott F, Newman L. (1996). Chronic fatigue syndrome: report of a joint working group of the Royal Colleges of Physicians, Psychiatrists and General Practitioners.
Twisk FNM, Arnoldus RJW. (2012). Graded exercise therapy (GET)/cognitive behavioural therapy (CBT) is often counterproductive in myalgic encephalomyelitis (ME) and chronic fatigue syndrome (CFS). Eur J Clin Invest.
Tyrer P, Seivewright H, Seivewright N. (1997). Diagnosis of ‘ME’, which makes an external attribution for fatigue. Psychol Med.
U.S. Preventive Services Task Force. (2008). U.S. Preventive Services Task Force Procedure Manual.
Ulloa L, Doody J, Massague J. (1999). Inhibition of transforming growth factor-beta/SMAD signalling by the interferon-gamma/STAT pathway. Nature.
Unger ER, Nisenbaum R, Moldofsky H, et al. (2004). Sleep assessment in a population-based study of chronic fatigue syndrome. BMC Neurol.
Ur E, White PD, Grossman A. (1992). Hypothesis: cytokines may be activated to cause depressive illness and chronic fatigue syndrome. Eur Arch Psychiatry Clin Neurosci.
Valero S, Saez-Francas N, Calvo N, et al. (2013). The role of neuroticism, perfectionism and depression in chronic fatigue syndrome. A structural equation modeling approach. Comprehensive Psychiatry.
Valesini G, Conti F, Priori R, et al. (1993). Gilbert’s syndrome and chronic fatigue syndrome. Lancet.
Van Cauwenbergh D, De Kooning M, Ickmans K, et al. (2012). How to exercise people with chronic fatigue syndrome: evidence-based practice guidelines. Eur J Clin Invest.
Van Cauwenbergh D, Nijs J, Kos D, et al. (2014). Malfunctioning of the autonomic nervous system in patients with chronic fatigue syndrome: a systematic literature review. Eur J Clin Invest.
van de Luit L, van der Meulen J, Cleophas TJ, et al. (1998). Amplified amplitudes of circadian rhythms and nighttime hypotension in patients with chronic fatigue syndrome: improvement by inopamil but not by melatonin. Angiology.
van de Putte EM, Engelbert RHH, Kuis W, et al. (2006). How fatigue is related to other somatic symptoms. Arch Dis Child.
van de Putte EM, Engelbert RHH, Kuis W, et al. (2005). Chronic fatigue syndrome and health control in adolescents and parents. Arch Dis Child.
van de Putte EM, van Doornen LJP, Engelbert RHH, et al. (2006). Mirrored symptoms in mother and child with chronic fatigue syndrome. Pediatrics.
Van Den Eede F, Moorkens G, Hulstijn W, et al. (2011). Psychomotor function and response inhibition in chronic fatigue syndrome. Psychiatry Res.
Van Den Eede F, Moorkens G, Hulstijn W, et al. (2008). Combined dexamethasone/corticotropin-releasing factor test in chronic fatigue syndrome. Psychol Med.
Van HE, Coomans D, De BP, et al. (2003). Hyperbaric Therapy in Chronic Fatigue Syndrome. J Chronic Fatigue Syndr.
van Heukelom RO, Prins JB, Smits MG, et al. (2006). Influence of melatonin on fatigue severity in patients with chronic fatigue syndrome and late melatonin secretion. Eur J Neurol.
Van Hoof E, De Becker P, Lapp C, et al. (2007). Defining the occurrence and influence of alpha-delta sleep in chronic fatigue syndrome. Am J Med Sci.
Van Houdenhove B, Luyten P. (2010). Chronic fatigue syndrome reflects loss of adaptability. J Intern Med.
Van Houdenhove B, Onghena P, Neerinckx E, et al. (1995). Does high ‘action-proneness’ make people more vulnerable to chronic fatigue syndrome? A controlled psychometric study. J Psychosom Res.
Van Houdenhove B, Van Hoof E, Becq K, et al. (2009). A comparison of patients with chronic fatigue syndrome in two “ideologically” contrasting clinics. J Nerv Ment Dis.
van Hout MSE, Wekking EM, Berg IJ, et al. (2003). Psychological treatment of patients with chronic toxic encephalopathy: lessons from studies of chronic fatigue and whiplash. Psychother Psychosom.
van Kuppeveld FJM, de Jong AS, Lanke KH, et al. (2010). Prevalence of xenotropic murine leukaemia virus-related virus in patients with chronic fatigue syndrome in the Netherlands: retrospective analysis of samples from an established cohort. BMJ.
Van Oosterwijck J, Nijs J, Meeus M, et al. (2010). Pain inhibition and postexertional malaise in myalgic encephalomyelitis/chronic fatigue syndrome: an experimental study. J Intern Med.
van Weering M, Vollenbroek-Hutten MMR, Kotte EM, et al. (2007). Daily physical activities of patients with chronic pain or fatigue versus asymptomatic controls. A systematic review. Clin Rehabil.
vanNess J, Snell C, Stevens S. (2008). Diminished Cardiopulmonary Capacity During Post-Exertional Malaise. J Chronic Fatigue Synr.
Vanness JM, Snell CR, Strayer DR, et al. (2003). Subclassifying chronic fatigue syndrome through exercise testing. Med Sci Sports Exerc.
Vassallo CM, Feldman E, Peto T, et al. (2001). Decreased tryptophan availability but normal post-synaptic 5-HT2c receptor sensitivity in chronic fatigue syndrome. Psychol Med.
Vecchiet J, Cipollone F, Falasca K, et al. (2003). Relationship between musculoskeletal symptoms and blood markers of oxidative stress in patients with chronic fatigue syndrome. Neurosci Lett.
Vecchiet L, Montanari G, Pizzigallo E, et al. (1996). Sensory characterization of somatic parietal tissues in humans with chronic fatigue syndrome. Neurosci Lett.
Vercoulen JH, Swanink CM, Zitman FG, et al. (1996). Randomised, double-blind, placebo-controlled study of fluoxetine in chronic fatigue syndrome. Lancet.
Vermeulen RCKRM, Scholte HR. Carnitine, acetylcarnitine and propionylcarnitine in the treatment of chronic fatigue syndrome. AHMF Proceedings, ‘myalgic Encephalopathy/chronic Fatigue Syndrome ‘the Medical Practitioners’ Challenge in 2001’.
Vernon SD, Unger ER, Dimulescu IM, et al. (2002). Utility of the blood for gene expression profiling and biomarker discovery in chronic fatigue syndrome. Dis Markers.
Vervarcke A. (2005). CFS trial in Leuven with CFS-PC: conclusions after one year. Homoeopathic Links.
Visser J, Blauw B, Hinloopen B, et al. (1998). CD4 T lymphocytes from patients with chronic fatigue syndrome have decreased interferon-gamma production and increased sensitivity to dexamethasone. J Infect Dis.
Visser J, Graffelman W, Blauw B, et al. (2001). LPS-induced IL-10 production in whole blood cultures from chronic fatigue syndrome patients is increased but supersensitive to inhibition by dexamethasone. J Neuroimmunol.
Vojdani A. (1999). Single aetiological agent may not be feasible in CFS patients. J Intern Med.
Vojdani A, Ghoneum M, Choppa PC, et al. (1997). Elevated apoptotic cell population in patients with chronic fatigue syndrome: the pivotal role of protein kinase RNA. J Intern Med.
Vollmer-Conna U, Hickie I, Hadzi-Pavlovic D, et al. (1997). Intravenous immunoglobulin is ineffective in the treatment of patients with chronic fatigue syndrome. Am J Med.
Vollmer-Conna U, Wakefield D, Lloyd A, et al. (1997). Cognitive deficits in patients suffering from chronic fatigue syndrome, acute infective illness or depression. Br J Psychiatry.
von Mikecz A, Konstantinov K, Buchwald DS, et al. (1997). High frequency of autoantibodies to insoluble cellular antigens in patients with chronic fatigue syndrome. Arthritis Rheum.
Vos-Vromans DC, Huijnen IP, Koke AJ, et al. (2013). Differences in physical functioning between relatively active and passive patients with Chronic Fatigue Syndrome. J Psychosom Res.
Vos-Vromans DCWM, Smeets RJEM, Rijnders LJM, et al. (2012). Cognitive behavioural therapy versus multidisciplinary rehabilitation treatment for patients with chronic fatigue syndrome: study protocol for a randomised controlled trial (FatiGo). Trials.
Waldman PN. (2001). Vitamin therapy in the treatment of depression associated with chronic fatigue syndrome. Dissertation Abstracts International.
Wallman KE, Morton AR, Goodman C, et al. (2005). Exercise prescription for individuals with chronic fatigue syndrome. Med J Aust.
Wallman KE, Morton AR, Goodman C, et al. (2004). Randomised controlled trial of graded exercise in chronic fatigue syndrome. Med J Aust.
Wang J-h, Chai T-q, Lin G-h, et al. (2009). Effects of the intelligent-turtle massage on the physical symptoms and immune functions in patients with chronic fatigue syndrome. J Tradit Chin Med.
Wang T, Zhang Q, Xue X, et al. (2008). A systematic review of acupuncture and moxibustion treatment for chronic fatigue syndrome in China. Am J Chin Med.
Ward MH, DeLisle H, Shores JH, et al. (1996). Chronic fatigue complaints in primary care: incidence and diagnostic patterns. J Am Osteopath Assoc.
Ware J, Kosinski M, Keller SD. (1996). A 12-Item Short-Form Health Survey: construction of scales and preliminary tests of reliability and validity. Med Care.
Ware JE, Sherbourne CD. (1992). The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care.
Warren G, McKendrick M, Peet M. (1999). The role of essential fatty acids in chronic fatigue syndrome. A case-controlled study of red-cell membrane essential fatty acids (EFA) and a placebo-controlled treatment study with high dose of EFA. Acta Neurol Scand.
Wearden A. (2007). Randomised controlled trial of nurse-led self-help treatment for patients in primary care with chronic fatigue syndrome. The FINE trial (Fatigue Intervention by Nurses Evaluation) [ISRCTN74156610 ]. controlled trialscom.
Wearden AJ, Riste L, Dowrick C, et al. (2006). Fatigue Intervention by Nurses Evaluation--the FINE Trial. A randomised controlled trial of nurse led self-help treatment for patients in primary care with chronic fatigue syndrome: study protocol. BMC Med.
Wells DL. (2009). Associations between pet ownership and self-reported health status in people suffering from chronic fatigue syndrome. J Altern Complement Med.
Wessely S. (1989). Acyclovir treatment of the chronic fatigue syndrome. N Engl J Med.
Wessely S. (1999). Cognitive behaviour therapy vs relaxation for Chronic Fatigue Syndrome: Outcome at five year follow-up. National Research Register.
Wessely S. (1992). The measurement of fatigue and chronic fatigue syndrome. J R Soc Med.
Wessely S. (1993). The neuropsychiatry of chronic fatigue syndrome. Ciba Found Symp.
Wessely S. (2000). A randomised controlled trial of cognitive behaviour therapy for chronic fatigue syndrome. National Research Register.
Wessely S, Chalder T, Hirsch S, et al. (1997). The prevalence and morbidity of chronic fatigue and chronic fatigue syndrome: a prospective primary care study. Am J Public Health.
Wessely S, Chalder T, Hirsch S, et al. (1996). Psychological symptoms, somatic symptoms, and psychiatric disorder in chronic fatigue and chronic fatigue syndrome: a prospective study in the primary care setting. Am J Psychiatry.
Wessely S, Powell R. (1989). Fatigue syndromes: a comparison of chronic “postviral” fatigue with neuromuscular and affective disorders. J Neurol Neurosurg Psychiatry.
Westin J, Rodjer S, Turesson I, et al. (1995). Interferon alfa-2b versus no maintenance therapy during the plateau phase in multiple myeloma: a randomized study. Cooperative Study Group. Br J Haematol.
Weston S, Townsend S. (2009). Using a DVD to help people with chronic fatigue syndrome learn the technique of pacing. Nurs Times.
White KP, Speechley M, Harth M, et al. (2000). Co-existence of chronic fatigue syndrome with fibromyalgia syndrome in the general population. A controlled study. Scand J Rheumatol.
White PD, Chalder T. (2012). Chronic fatigue syndrome: treatment without a cause. Lancet.
White PD, Pinching AJ, Rakib A, et al. (2002). A comparison of patients with chronic fatigue syndrome attending separate fatigue clinics based in immunology and psychiatry. J R Soc Med.
White PD, Thomas JM, Kangro HO, et al. (2001). Predictions and associations of fatigue syndromes and mood disorders that occur after infectious mononucleosis. Lancet.
Whitehead L, Campion P. (2002). Can general practitioners manage Chronic Fatigue Syndrome? A controlled trial. J Chronic Fatigue Syndr.
Whiteside A, Hansen S, Chaudhuri A. (2004). Exercise lowers pain threshold in chronic fatigue syndrome. Pain.
Whiting P, Bagnall AM, Sowden AJ, et al. (2001). Interventions for the treatment and management of chronic fatigue syndrome: a systematic review. JAMA.
Wiborg JF, Knoop H, Frank LE, et al. (2012). Towards an evidence-based treatment model for cognitive behavioral interventions focusing on chronic fatigue syndrome. J Psychosom Res.
Wiborg JF, Knoop H, Prins JB, et al. (2011). Does a decrease in avoidance behavior and focusing on fatigue mediate the effect of cognitive behavior therapy for chronic fatigue syndrome?. J Psychosom Res.
Wiborg JF, Knoop H, Stulemeijer M, et al. (2010). How does cognitive behaviour therapy reduce fatigue in patients with chronic fatigue syndrome? The role of physical activity. Psychol Med.
Wiklund I. (1990). The Nottingham Health Profile--a measure of health-related quality of life. Scand J Prim Health Care Suppl.
Wildman MJ, Smith EG, Groves J, et al. (2002). Chronic fatigue following infection by Coxiella burnetii (Q fever): ten-year follow-up of the 1989 UK outbreak cohort. QJM.
Wilke WS. (2001). Can fibromyalgia and chronic fatigue syndrome be cured by surgery?. Cleve Clin J Med.
Wilkinson K, Shapiro C. (2012). Nonrestorative sleep: symptom or unique diagnostic entity?. Sleep Med.
Wilson A, Hickie I, Hadzi-Pavlovic D, et al. (2001). What is chronic fatigue syndrome? Heterogeneity within an international multicentre study. Aust N Z J Psychiatry.
Wisniewski SR, Rush AJ, Balasubramani GK, et al. (2006). Self-rated global measure of the frequency, intensity, and burden of side effects. J Psychiatr Pract.
Wojcik W, Armstrong D, Kanaan R. (2011). Chronic fatigue syndrome: labels, meanings and consequences. J Psychosom Res.
Wong KC. (2009). Psychometric investigation into the construct of neurasthenia and its related conditions: A comparative study on Chinese in Hong Kong and mainland China. Dissertation Abstracts International.
Wong R, Lopaschuk G, Zhu G, et al. (1992). Skeletal muscle metabolism in the chronic fatigue syndrome. In vivo assessment by 31P nuclear magnetic resonance spectroscopy. Chest.
Wong WS, Fielding R. (2010). Prevalence of chronic fatigue among Chinese adults in Hong Kong: a population-based study. J Affect Disord.
Woo SB, Schacterle RS, Komaroff AL, et al. (2000). Salivary gland changes in chronic fatigue syndrome: a case-controlled preliminary histologic study. Oral Surg Oral Med Oral Pathol Oral Radiol Endod.
Wood PB. (2005). Neuroimaging in functional somatic syndromes. Int Rev Neurobiol.
Wright B, Ashby B, Beverley D, et al. (2005). A feasibility study comparing two treatment approaches for chronic fatigue syndrome in adolescents. Arch Dis Child.
Yamamoto Y, LaManca JJ, Natelson BH. (2003). A measure of heart rate variability is sensitive to orthostatic challenge in women with chronic fatigue syndrome. Exp Biol Med.
Yee CW, Chellappan DK. (2013). Are the current complementary and alternative therapies available for the treatment of low back pain and chronic fatigue syndrome reliable clinically? A review of the literature. J Evid Based Complementary Altern Med.
Yoshiuchi K, Cook DB, Ohashi K, et al. (2007). A real-time assessment of the effect of exercise in chronic fatigue syndrome. Physiol Behav.
Yoshiuchi K, Quigley KS, Ohashi K, et al. (2004). Use of time-frequency analysis to investigate temporal patterns of cardiac autonomic response during head-up tilt in chronic fatigue syndrome. Auton Neurosci.
Young JL. (2010). Use of Lisdexamfetamine Dimesylate in Treatment of Cognitive Impairment (Chronic Fatigue Syndrome): A Double Blind, Placebo Controlled Study [NCT01071044]. Clinicaltrials.gov.
Young JL. (2013). Use of lisdexamfetamine dimesylate in treatment of executive functioning deficits and chronic fatigue syndrome: A double blind, placebo-controlled study. Psychiatry Res.
Yuemei L, Hongping L, Shulan F, et al. (2006). The therapeutic effects of electrical acupuncture and auricular-plaster in 32 cases of chronic fatigue syndrome. J Tradit Chin Med.
Zachrisson O, Colque-Navarro P, Gottfries CG, et al. (2004). Immune modulation with a staphylococcal preparation in fibromyalgia/chronic fatigue syndrome: relation between antibody levels and clinical improvement. Eur J Clin Microbiol Infect Dis.
Zachrisson O, Regland B, Jahreskog M, et al. (2002). Treatment with staphylococcus toxoid in fibromyalgia/chronic fatigue syndrome--a randomised controlled trial. Eur J Pain.
Zachrisson O, Regland B, Jahreskog M, et al. (2002). A rating scale for fibromyalgia and chronic fatigue syndrome (the FibroFatigue scale). J Psychosom Res.
Zala J. (1989). Diagnosing myalgic encephalomyelitis. Practitioner.
Zhang H-Y, Liu Z-D, Hu C-J, et al. (2011). Up-regulation of TGF-1 mRNA expression in peripheral blood mononuclear cells of patients with chronic fatigue syndrome. J Formos Med Assoc.
Zhang W, Wu T, Peng W. (2011). Acupuncture for chronic fatigue syndrome. Cochrane Database Syst Rev.
Zigmond AS, Snaith RP. (1983). The hospital anxiety and depression scale. Acta Psychiatr Scand.
Zung WW. (1965). A Self-Rating Depression Scale. Arch Gen Psychiatry.