# Appendix C List of Included Studies

Asbring P, Narvanen A-L. (2002). Women’s experiences of stigma in relation to chronic fatigue syndrome and fibromyalgia. Qual Health Res.
Aslakson E, Vollmer-Conna U, White PD. (2006). The validity of an empirical delineation of heterogeneity in chronic unexplained fatigue. Pharmacogenomics.
Assefi NP, Coy TV, Uslan D, et al. (2003). Financial, occupational, and personal consequences of disability in patients with chronic fatigue syndrome and fibromyalgia compared to other fatiguing conditions. J Rheumatol.
Bazelmans E, Prins JB, Lulofs R, et al. (2005). Cognitive behaviour group therapy for chronic fatigue syndrome: a non-randomised waiting list controlled study. Psychother Psychosom.
Blacker CVR, Greenwood DT, Wesnes KA, et al. (2004). Effect of galantamine hydrobromide in chronic fatigue syndrome: a randomized controlled trial. JAMA.
Blockmans D, Persoons P, Van Houdenhove B, et al. (2003). Combination therapy with hydrocortisone and fludrocortisone does not improve symptoms in chronic fatigue syndrome: a randomized, placebo-controlled, double-blind, crossover study. Am J Med.
Brimmer DJ, Maloney E, Devlin R, et al. (2013). A pilot registry of unexplained fatiguing illnesses and chronic fatigue syndrome. BMC Res Notes.
Brown AA, Jason LA, Evans MA, et al. (2013). Contrasting case definitions: The ME International Consensus Criteria vs. the Fukuda et al. CFS criteria. N Am J Psychol.
Burgess M, Andiappan M, Chalder T. (2012). Cognitive behaviour therapy for chronic fatigue syndrome in adults: face to face versus telephone treatment: a randomized controlled trial. Behav Cogn Psychother.
Chan JSM, Ho RTH, Wang CW, et al. (2013). Effects of qigong exercise on fatigue, anxiety, and depressive symptoms of patients with chronic fatigue syndrome-like illness: A randomized controlled trial. Evidence based Complementary and Alternative Medicine.
Davenport TE, Stevens SR, Baroni K, et al. (2011). Reliability and validity of Short Form 36 Version 2 to measure health perceptions in a sub-group of individuals with fatigue. Disabil Rehabil.
Davenport TE, Stevens SR, Baroni K, et al. (2011). Diagnostic accuracy of symptoms characterising chronic fatigue syndrome. Disabil Rehabil.
Deale A, Chalder T, Marks I, et al. (1997). Cognitive behavior therapy for chronic fatigue syndrome: a randomized controlled trial. Am J Psychiatry.
Deale A, Husain K, Chalder T, et al. (2001). Long-term outcome of cognitive behavior therapy versus relaxation therapy for chronic fatigue syndrome: a 5-year follow-up study. Am J Psychiatry.
Deale A, Wessely S. (2000). Diagnosis of psychiatric disorder in clinical evaluation of chronic fatigue syndrome. J R Soc Med.
Devasahayam A, Lawn T, Murphy M, et al. (2012). Alternative diagnoses to chronic fatigue syndrome in referrals to a specialist service: service evaluation survey. JRSM short reports.
Diaz-Mitoma F, Turgonyi E, Kumar A, et al. (2003). Clinical improvement in chronic fatigue syndrome is associated with enhanced natural killer cell-mediated cytotoxicity: The results of a pilot study with Isoprinosine. J Chronic Fatigue Syndr.
Dickson A, Knussen C, Flowers P. (2007). Stigma and the delegitimation experience: An interpretative phenomenological analysis of people living with chronic fatigue syndrome. Psychol Health.
Dougall D, Johnson A, Goldsmith K, et al. (2014). Adverse events and deterioration reported by participants in the PACE trial of therapies for chronic fatigue syndrome. J Psychosom Res.
Fulcher KY, White PD. (1997). Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ.
Gaab J, Engert V, Heitz V, et al. (2004). Associations between neuroendocrine responses to the Insulin Tolerance Test and patient characteristics in chronic fatigue syndrome. J Psychosom Res.
Gaab J, Huster D, Peisen R, et al. (2002). Low-dose dexamethasone suppression test in chronic fatigue syndrome and health. Psychosom Med.
Gaab J, Rohleder N, Heitz V, et al. (2005). Stress-induced changes in LPS-induced pro-inflammatory cytokine production in chronic fatigue syndrome. Psychoneuroendocrinology.
Goudsmit EM, Ho-Yen DO, Dancey CP. (2009). Learning to cope with chronic illness. Efficacy of a multi-component treatment for people with chronic fatigue syndrome. Patient Educ Couns.
Green J, Romei J, Natelson BH. (1999). Stigma and chronic fatigue syndrome. J Chronic Fatigue Syndr.
Guise J, McVittie C, McKinlay A. (2010). A discourse analytic study of ME/CFS (Chronic Fatigue Syndrome) sufferers’ experiences of interactions with doctors. J Health Psychol.
Hadzi-Pavlovic D, Hickie IB, Wilson AJ, et al. (2000). Screening for prolonged fatigue syndromes: validation of the SOFA scale. Soc Psychiatry Psychiatr Epidemiol.
Hlavaty LE, Brown MM, Jason LA. (2011). The effect of homework compliance on treatment outcomes for participants with myalgic encephalomyelitis/chronic fatigue syndrome. Rehabil Psychol.
Ho RTH, Chan JSM, Wang C-W, et al. (2012). A randomized controlled trial of qigong exercise on fatigue symptoms, functioning, and telomerase activity in persons with chronic fatigue or chronic fatigue syndrome. Ann Behav Med.
Hobday RA, Thomas S, O’Donovan A, et al. (2008). Dietary intervention in chronic fatigue syndrome. J Hum Nutr Diet.
Jason L, Benton M, Torres-Harding S, et al. (2009). The impact of energy modulation on physical functioning and fatigue severity among patients with ME/CFS. Patient Educ Couns.
Jason L, Brown M, Evans M, et al. (2011). Measuring substantial reductions in functioning in patients with chronic fatigue syndrome. Disabil Rehabil.
Jason LA, Brown A, Clyne E, et al. (2012). Contrasting case definitions for chronic fatigue syndrome, Myalgic Encephalomyelitis/chronic fatigue syndrome and myalgic encephalomyelitis. Eval Health Prof.
Jason LA, Brown A, Evans M, et al. (2013). Contrasting chronic Fatigue syndrome versus myalgic encephalomyelitis/chronic fatigue syndrome. Fatigue.
Jason LA, Evans M, Brown A, et al. (2010). Sensitivity and specificity of the CDC empirical chronic fatigue syndrome case definition. Psychology.
Jason LA, Roesner N, Porter N, et al. (2010). Provision of social support to individuals with chronic fatigue syndrome. J Clin Psychol.
Jason LA, Sunnquist M, Brown A, et al. (2014). Are Myalgic Encephalomyelitis and chronic fatigue syndrome different illnesses? A preliminary analysis. J Health Psychol.
Jason LA, Taylor RR. (2001). Measuring attributions about chronic fatigue syndrome. J Chronic Fatigue Syndr.
Jason LA, Taylor RR, Stepanek Z, et al. (2001). Attitudes regarding chronic fatigue syndrome: The importance of a name. J Health Psychol.
Jason LA, Torres-Harding S, Friedberg F, et al. (2007). Non-pharmacologic interventions for CFS: a randomized trial. J Clin Psychol Med Settings.
Jason LA, Torres-Harding SR, Jurgens A, et al. (2004). Comparing the Fukuda et al. criteria and the Canadian case definition for chronic fatigue syndrome. J Chronic Fatigue Syndr.
Jason LA, Torres-Harding SR, Taylor RR, et al. (2001). A comparison of the 1988 and 1994 diagnostic criteria for chronic fatigue syndrome. J Clin Psychol Med Settings.
Katon WJ, Buchwald DS, Simon GE, et al. (1991). Psychiatric illness in patients with chronic fatigue and those with rheumatoid arthritis. J Gen Intern Med.
Knoop H, van der Meer JWM, Bleijenberg G. (2008). Guided self-instructions for people with chronic fatigue syndrome: randomised controlled trial. Br J Psychiatry.
Komaroff AL, Fagioli LR, Doolittle TH, et al. (1996). Health status in patients with chronic fatigue syndrome and in general population and disease comparison groups. Am J Med.
Lawn T, Kumar P, Knight B, et al. (2010). Psychiatric misdiagnoses in patients with chronic fatigue syndrome. JRSM short reports.
Lewis I, Pairman J, Spickett G, et al. (2013). Is chronic fatigue syndrome in older patients a different disease? -- a clinical cohort study. Eur J Clin Invest.
Linder R, Dinser R, Wagner M, et al. (2002). Generation of classification criteria for chronic fatigue syndrome using an artificial neural network and traditional criteria set. In Vivo.
Lopez C, Antoni M, Penedo F, et al. (2011). A pilot study of cognitive behavioral stress management effects on stress, quality of life, and symptoms in persons with chronic fatigue syndrome. J Psychosom Res.
McKenzie R, O’Fallon A, Dale J, et al. (1998). Low-dose hydrocortisone for treatment of chronic fatigue syndrome: a randomized controlled trial. JAMA.
Montoya JG, Kogelnik AM, Bhangoo M, et al. (2013). Randomized clinical trial to evaluate the efficacy and safety of valganciclovir in a subset of patients with chronic fatigue syndrome. J Med Virol.
Moss-Morris R, Sharon C, Tobin R, et al. (2005). A randomized controlled graded exercise trial for chronic fatigue syndrome: outcomes and mechanisms of change. J Health Psychol.
Newton JL, Mabillard H, Scott A, et al. (2010). The Newcastle NHS Chronic Fatigue Syndrome Service: not all fatigue is the same. J R Coll Physicians Edinb.
Núñez M, Fernandez-Sola J, Núñez E, et al. (2011). Health-related quality of life in patients with chronic fatigue syndrome: group cognitive behavioural therapy and graded exercise versus usual treatment. A randomised controlled trial with 1year of follow-up. Clin Rheumatol.
Öckerman PA. (2000). Antioxidant treatment of chronic fatigue syndrome. Clin Pract Alternat Med.
O’Dowd H, Gladwell P, Rogers CA, et al. (2006). Cognitive behavioural therapy in chronic fatigue syndrome: a randomised controlled trial of an outpatient group programme. Health Technol Assess.
Peterson PK, Shepard J, Macres M, et al. (1990). A controlled trial of intravenous immunoglobulin G in chronic fatigue syndrome. Am J Med.
Reyes M, Nisenbaum R, Hoaglin DC, et al. (2003). Prevalence and incidence of chronic fatigue syndrome in Wichita, Kansas. Arch Intern Med.
Sharpe M, Hawton K, Simkin S, et al. (1996). Cognitive behaviour therapy for the chronic fatigue syndrome: a randomized controlled trial. BMJ.
Strayer DR, Carter WA, Brodsky I, et al. (1994). A controlled clinical trial with a specifically configured RNA drug, poly(I) midline dot poly(C12U), in chronic fatigue syndrome. Clin Infect Dis.
Strayer DR, Carter WA, Stouch BC, et al. (2012). A double-blind, placebo-controlled, randomized, clinical trial of the TLR-3 agonist rintatolimod in severe cases of chronic fatigue syndrome. PLoS ONE.
Sutcliffe K, Gray J, Tan MP, et al. (2010). Home orthostatic training in chronic fatigue syndrome--a randomized, placebo-controlled feasibility study. Eur J Clin Invest.
Taylor RR. (2004). Quality of life and symptom severity for individuals with chronic fatigue syndrome: findings from a randomized clinical trial. Am J Occup Ther.
The GKH, Bleijenberg G, van der Meer JWM. (2007). The effect of acclydine in chronic fatigue syndrome: A randomized controlled trial. PLoS Clinical Trials.
Tiev KP, Demettre E, Ercolano P, et al. (2003). RNase L levels in peripheral blood mononuclear cells: 37-kilodalton/83-kilodalton isoform ratio is a potential test for chronic fatigue syndrome. Clin Diagn Lab Immunol.
Tummers M, Knoop H, Bleijenberg G. (2010). Effectiveness of stepped care for chronic fatigue syndrome: a randomized noninferiority trial. J Consult Clin Psychol.
Tummers M, Knoop H, van Dam A, et al. (2012). Implementing a minimal intervention for chronic fatigue syndrome in a mental health centre: a randomized controlled trial. Psychol Med.
Tummers M, Knoop H, van Dam A, et al. (2013). Moderators of the treatment response to guided self-instruction for chronic fatigue syndrome. J Psychosom Res.
Van Hoof E, De Meirleir K. (2005). Chronic Fatigue Syndrome and Myalgic Encephalomyletis: Are Both Conditions on the Same Continuum?. N Am J Psychol.
Vermeulen RCW, Scholte HR. (2004). Exploratory open label, randomized study of acetyl- and propionylcarnitine in chronic fatigue syndrome. Psychosom Med.
Walach H, Bosch H, Lewith G, et al. (2008). Effectiveness of distant healing for patients with chronic fatigue syndrome: a randomised controlled partially blinded trial (EUHEALS). Psychother Psychosom.
Watson SP, Ruskin AS, Simonis V, et al. (2014). Identifying Defining Aspects of Chronic Fatigue Syndrome via Unsupervised Machine Learning and Feature Selection. International Journal of Machine Learning & Computing.
Wearden AJ, Dowrick C, Chew-Graham C, et al. (2010). Nurse led, home based self help treatment for patients in primary care with chronic fatigue syndrome: randomised controlled trial. BMJ.
Wearden AJ, Dunn G, Dowrick C, et al. (2012). Depressive symptoms and pragmatic rehabilitation for chronic fatigue syndrome. Br J Psychiatry.
Wearden AJ, Emsley R. (2013). Mediators of the effects on fatigue of pragmatic rehabilitation for chronic fatigue syndrome. J Consult Clin Psychol.
Wearden AJ, Morriss RK, Mullis R, et al. (1998). Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome. Br J Psychiatry.
Weatherley-Jones E, Nicholl JP, Thomas KJ, et al. (2004). A randomised, controlled, triple-blind trial of the efficacy of homeopathic treatment for chronic fatigue syndrome. J Psychosom Res.
White PD, Goldsmith K, Johnson AL, et al. (2013). Recovery from chronic fatigue syndrome after treatments given in the PACE trial. Psychol Med.
White PD, Goldsmith KA, Johnson AL, et al. (2011). Comparison of adaptive pacing therapy, cognitive behaviour therapy, graded exercise therapy, and specialist medical care for chronic fatigue syndrome (PACE): a randomised trial. Lancet.
Williams G, Waterhouse J, Mugarza J, et al. (2002). Therapy of circadian rhythm disorders in chronic fatigue syndrome: no symptomatic improvement with melatonin or phototherapy. Eur J Clin Invest.
Woodward RV, Broom DH, Legge DG. (1995). Diagnosis in chronic illness: disabling or enabling--the case of chronic fatigue syndrome. J R Soc Med.