# Appendix B Inclusion and Exclusion Criteria

Table B1 Inclusion and exclusion criteria

| Include | Exclude
Population | [underlined: KQ 1:] Symptomatic adults ≥18 years old with fatigue [underlined: KQ 2]: Symptomatic adults ≥18 years, diagnosed with ME, CFS, or both and without another underlying diagnosis | [underlined: All KQs:] Populations containing children or adolescents. Patients with another underlying diagnosis.
Interventions | [underlined: KQ 1:] Case definitions (e.g., Fukuda/CDC, Canadian, International, and others) [underlined: KQ 2]: Forms of counseling and behavior therapy, graded exercise programs, complementary and alternative medicine (acupuncture, relaxation, massage, other), and symptom-based medication management (immune modulators, beta blockers, antidepressants, anxiolytics, stimulants, other) | [underlined: KQ 2:] Medications not available in the U.S.
Comparators | [underlined: KQ 1]: Diagnostic accuracy studies and diagnostic concordance studies [underlined: KQ 2:] Placebo, no treatment, usual care, other active interventions (including combination therapies and head-to-head trials) | [underlined: KQ 1]: No comparator [underlined: KQ 2:] No comparator
Outcomes | [underlined: KQ 1]: Sensitivity, specificity, positive predictive value, negative predictive value, positive likelihood ratio, negative likelihood ratio, C statistic (AUROC), net reclassification index; concordance, any potential harm from diagnosis (such as psychological harms, labeling, risk from diagnostic test, misdiagnosis, other) [underlined: KQ 2:] Overall function (i.e. 36-item Short Form Survey), quality of life, days spent at work/school, proportion working full- or part-time, fatigue (Multidimensional Fatigue Inventory or similar), adverse effects of interventions, withdrawals and withdrawals due to adverse events, rates of adverse events due to interventions | [underlined: KQ 1:] Not listed as an included outcome [underlined: KQ 2:] Not listed as an included outcome
Settings | [underlined: All KQs:] Clinical settings and those generalizable to a U.S. primary care setting | [underlined: All KQs]: Studies performed in countries with populations not similar to the U.S.; studies conducted in schools or work-sites, unless primary-care feasible
Timing | [underlined: KQ 1:] Any duration [underlined: KQ 2:] ≥12 weeks of treatment | [underlined: KQ 1:] None [underlined: KQ 2:] <12 weeks of treatment
Study types and designs | [underlined: All KQ:] Studies published in 1988 or after [underlined: KQ 2]: Systematic reviews or meta-analyses of randomized or controlled clinical trials, primary reports of randomized or controlled clinical trials, and large cohort studies | [underlined: All KQ:] Non-systematic reviews, letters to the editor, before and after studies, case-control studies, non-comparative studies; reviews not in English; and studies published before 1988

Abbreviations: AUROC = area under the receiver operating characteristics curve; CDC = Centers for Disease Control and Prevention; CFS = chronic fatigue syndrome; KQ = key question; ME = myalgic encephalomyelitis; U.S. = United States