# Appendix A Search Strategies

## Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1988 to September Week 3 2014>

### Search Strategy

1. exp Fatigue Syndrome, Chronic/
2. exp Encephalomyelitis/
3. exp Fatigue/
4. 2 and 3
5. 1 or 4
6. (chronic$ adj3 fatig$ adj3 syndrom$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
7. (myalg$ adj3 encephal$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
8. 6 or 7
9. 5 or 8
10. limit 9 to english language
11. limit 9 to abstracts
12. 10 or 11

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials <September 2014>

### Search Strategy

1. (chronic$ adj3 fatig$ adj3 syndrom$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (myalg$ adj3 encephal$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 or 2

## Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to September 2014>

### Search Strategy

1. (chronic$ adj3 fatig$ adj3 syndrom$).mp. [mp=title, abstract, full text, keywords, caption text]
2. (myalg$ adj3 encephal$).mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 or 2

## Database: EBM Reviews - Database of Abstracts of Reviews of Effects <3rd Quarter 2014>

### Search Strategy

1. (chronic$ adj3 fatig$ adj3 syndrom$).mp. [mp=title, full text, keywords]
2. (myalg$ adj3 encephal$).mp. [mp=title, full text, keywords]
3. 1 or 2

## Database: EBM Reviews - Health Technology Assessment <3rd Quarter 2014>

### Search Strategy

1. (chronic$ adj3 fatig$ adj3 syndrom$).mp. [mp=title, text, subject heading word]
2. (myalg$ adj3 encephal$).mp. [mp=title, text, subject heading word]
3. 1 or 2

## Database: EBM Reviews - NHS Economic Evaluation Database <3rd Quarter 2014>

### Search Strategy

1. (chronic$ adj3 fatig$ adj3 syndrom$).mp. [mp=title, text, subject heading word]
2. (myalg$ adj3 encephal$).mp. [mp=title, text, subject heading word]
3. 1 or 2

## Database: PsycINFO <1988 to September Week 3 2014>

### Search Strategy

1. exp Chronic Fatigue Syndrome/
2. exp Encephalomyelitis/
3. exp Fatigue/
4. 2 and 3
5. 1 or 4
6. (chronic$ adj3 fatig$ adj3 syndrom$).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
7. (myalg$ adj3 encephal$).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
8. 6 or 7
9. 5 or 8
10. limit 9 to english language
11. limit 9 to abstracts
12. 10 or 11