# July 2016 Addendum

## Introduction

The AHRQ evidence report on the Diagnosis and Treatment of Myalgic Encephalomyelitis/Chronic Fatigue Syndrome was published in December, 2014 and provided a literature review for the National Institutes of Health Pathways to Prevention Workshop on Advancing the Research on Myalgic Encephalomyelitis/Chronic Fatigue Syndrome.1, 2 The review found eight case definitions for either chronic fatigue syndrome (CFS), myalgic encephalomyelitis (ME), or ME/CFS, and since its publication, an additional case definition was published by the Institute of Medicine along with the recommendation of a new name, Systemic Exertional Intolerance Disease.3 The Oxford (Sharpe, 1991) case definition is the least specific of the definitions and less generalizable to the broader population of patients with ME/CFS. It could identify individuals who have had 6 months of unexplained fatigue with physical and mental impairment, but no other specific features of ME/CFS such as post-exertional malaise which is considered by many to be a hallmark symptom of the disease.3 As a result, using the Oxford case definition results in a high risk of including patients who may have an alternate fatiguing illness or whose illness resolves spontaneously with time. In light of this, we recommended in our report that future intervention studies use a single agreed upon case definition, other than the Oxford (Sharpe, 1991) case definition. If a single definition could not be agreed upon, future research should retire the use of the Oxford (Sharpe, 1991) case definition. The National Institute of Health (NIH) panel assembled to review evidence presented at the NIH Pathways to Prevention Workshop agreed with our recommendation, stating that the continued use of the Oxford (Sharpe, 1991) case definition “may impair progress and cause harm.”2 In light of this, we have received public comment requesting a separation of results based on case definition to appraise the impact of Oxford based trials on conclusions of the report. Additionally, the public has requested that we separate cognitive behavioral therapy (CBT) from other counseling and behavioral interventions given that CBT is a specific therapeutic approach.

The purpose of this addendum to our original report is to assess the impact of studies using the Oxford (Sharpe, 1991) case definition on conclusions and to assess the impact of separating studies of cognitive behavioral therapy from other counseling and behavioral interventions.

## Results

### What are the (a) benefits and (b) harms of therapeutic interventions for patients with ME/CFS, and how do they vary by patient subgroups?

All intervention trials used a case definition for CFS as eligibility for trial inclusion. The results may not be applicable to individuals fulfilling criteria for ME or ME/CFS. Harms are generally poorly reported and conclusions surrounding harms are not impacted by this further analysis.

#### Medications

Of the nine studies that met inclusion criteria for medical treatment of ME/CFS, eight studies used a CDC (Holmes or Fukuda) case definition for CFS4-11 and one study used the Oxford (Sharpe, 1991) case definition for CFS.12 This latter study was the only trial comparing a selective serotonin reuptake inhibitor (fluoxetine) with a placebo or graded exercise therapy and found no significant differences on measures of fatigue or function with fluoxetine although there were greater withdrawals in the fluoxetine group (13% [9/68] vs. 3% [2/68]). We previously found the evidence on fluoxetine's effect on function or fatigue to be insufficient, such that consideration of the impact of the Oxford (Sharpe, 1991) case definition does not change this conclusion. Because the Oxford (Sharpe, 1991) case definition was not used in other medication trials, there remains low strength of evidence that Rintatolimod improves work capacity compared with placebo based on two randomized controlled trials10, 11 and insufficient evidence on the effectiveness of all other medications reviewed.

#### Complementary and Alternative Medicine Therapies

Of the seven trials that met inclusion criteria for the use of a complementary and alternative medicine (CAM) approach in treating ME/CFS, five studies used the CDC (Fukuda, 1994) case definition13-17 and two studies used the Oxford (Sharpe, 1991) case definition.18, 19 The latter two studies included a trial by Weatherly-Jones et al., that compared homeopathy with placebo and a trial by Williams et al., that compared melatonin with phototherapy or placebo. These trials as well as all of the other CAM trials were small, single studies, and there remains insufficient evidence on the effectiveness of diets, supplements, or phototherapy.

#### Counseling and Behavior Therapies

Of the 14 counseling and/or behavioral therapy trials included, several with multiple publications, eight compared CBT with another intervention or wait list control20-30 while six studies used a different counseling or behavioral technique.31-39 One of the CBT trials that used the CDC (Fukuda, 1994) case definition compared telephone CBT with face-to-face CBT and does not contribute to the addendum.2

##### Cognitive Behavioral Therapy

Two of seven remaining CBT studies used the Oxford case definition for eligibility (n=841)29, 30 (Table 1), while five studies used case definitions that ultimately fulfilled the CDC (Fukuda, 1994) case definition (n=800) (Table 2). Of note, one of these studies fulfilled both the Oxford (Sharpe, 1991) and the CDC (Fukuda, 1994) case definition.22, 23 Any differences in findings between the studies using the Oxford (Sharpe, 1991) and the CDC (Fukuda, 1994) case definitions are discussed by outcome below.

Table 1 Cognitive behavioral therapy trials using Oxford case definition for inclusion

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Outcomes Reported | Benefit
Sharpe, et al., 1996^29^ N= 60 Good | Oxford (Sharpe 1991) criteria | 12 months | A. CBT; B. Usual care | Function | Improved function
White, et al., 2011^30^ PACE Trial N=480 Good | Oxford (Sharpe, 1991) criteria | 13 months (52 weeks) | A. CBT; B. APT; C. GET; D. Usual care | Function, Fatigue, Employment, Global Impression, Harms | Improved all outcomes (CBT, GET) CBT vs. GET NS Fewest adverse events with CBT

Abbreviations: APT = adaptive pacing therapy; CBT = cognitive behavioral therapy; GET = graded exercise therapy; NS = not significant.

Table 2 Cognitive behavioral therapy trials using non-Oxford case definitions for inclusion

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Outcomes Reported | Benefit
Bazelmans, et al., 2005^20^ Nonrandomized trial N=65 Fair | CDC (Fukuda, 1994) | 6 months | A. Group CBT; B. Wait list control | Function, Fatigue, Employment | Worsening function in control
Deale, et al., 1997^22^ N=60 Deale, et al., 2001^23^ N=53 Fair | CDC (Schluederberg, 1992) criteria and Oxford (Sharpe, 1991) | Deale, 1997: 6 months Deale, 2001: 5 years | A. CBT; B. Relaxation | Function, Fatigue, Employment, Global Improvement, and 5-year follow up of symptoms, recovery, relapse | Improved all outcomes
Jason, et al., 2007^26^ Jason, et al., 2009^25^ Hlavaty, et al., 2011^24^ N=114 Fair | CFS Questionnaire, psychiatric assessment for DSM-IV diagnosis, and medical assessment | 12 months | A. CBT; B. COG; C. ACT; D. Relaxation | Function, Fatigue, Quality of Life, Employment | Improved function and fatigue
Lopez, et al., 2011^27^ N=58 Poor | CDC (Fukuda, 1994) criteria | 3 months (12 weeks) | A. Group CBT; B. Control, 1 session of psychoeducation summarizing strategies | Fatigue, Quality of Life | Improved quality of life
O'Dowd, et al., 2006^28^ N=153 Fair | CDC (Fukuda, 1994) criteria | 12 months | A. Group CBT; B. Group support; C. Usual care | Function, Fatigue, Quality of Life | Improved fatigue with CBT

Abbreviations: ACT = anaerobic activity therapy; CBT = cognitive behavioral therapy; CDC = Centers for Disease Control and Prevention; COG = cognitive therapy; DSM-IV = Diagnostic and Statistical Manual fourth edition.

###### Function

Function was evaluated in six trials (n=932). Statistically significant between group improvement in measures of function were found with CBT in both trials using the Oxford (Sharpe, 1991) case definition (n=540)29, 30 and in two of the four other trials. (n=174).22-26 Of the two trials that found no improvement, one trial found worsening function in the usual care group with stable function in the CBT group (F=9.12, p=0.004),20 and one trial found no difference, n=153.^28^ We performed a meta-analysis of four trials that considered the 36-item Short Form (SF-36) physical function subscale (range 0-100) as an outcome (including one trial that used the Oxford [Sharpe, 1991] case definition) and found a trend toward improvement but no statistically significant difference (weighted mean difference [WMD] 10.46, 95% confidence interval [CI], -7.47 to 27.77, Figure 1). We repeated the meta-analysis excluding the single Oxford based trial and found similar results (WMD 9.16, 95% CI, -10.28 to 28.6). We also repeated the meta-analysis excluding one trial that was an outlier and this found benefit from CBT with a more precise point estimate (WMD 6.02, 95% CI, 1.05 to 10.99). Two trials, one based on Oxford and one on CDC (Fukuda, 1994) case definitions, used alternative measures of function. The Oxford based trial found benefit as measured by the Karnofsky Performance Scale (n=60),29 while the CDC based trial found worsening function in the control group using the Sickness Impact Profile 8-items (n=60).20

Figure 1 Effects of cognitive behavioral therapies on physical function

Abbreviations: CI = confidence interval; N = sample size; SD = standard deviation.

Figure 1 is a forest plot of 4 studies reporting the weighted mean differences in changes on the SF-36 physical functioning subscale for cognitive behavioral therapy versus controls. Data for Figure 1 are presented in Tables 1 and 2. This figure is described further on pages 3 and 4 as follows: “We performed a meta-analysis of four trials that considered the 36-item Short Form (SF-36) physical function subscale (range 0-100) as an outcome and found a trend toward improvement but no statistically significant difference (weighted mean difference [WMD] 10.46, 95% confidence interval [CI], -7.47 to 27.77, Figure 1). We repeated the meta-analysis excluding the single Oxford based trial and found similar results (WMD 9.16, 95% CI, -10.28 to 28.6). We also repeated the meta-analysis excluding one trial that was an outlier and this found benefit from cognitive behavioral therapy with a more precise point estimate (WMD 6.02, 95% CI, 1.05 to 10.99).”

Based on these results, the overall analyses of function outcomes, including the studies using Oxford (Sharpe, 1991) case definition inclusion criteria, provided low strength of evidence that CBT improves function. In removing the two Oxford case definition based studies, we are left with four fair-quality studies, two finding benefit (n=174), one finding no benefit (n=153), and one finding stable function in the CBT group but worsening function in the usual care group (n=65). Unlike the positive results of the Oxford based trials, the results of the trials fulfilling the CDC criteria are mixed and would provide insufficient evidence to determine the effectiveness of CBT on the outcome of function due to study limitations, inconsistency and imprecision of results.

###### Fatigue

Fatigue outcomes were evaluated in six trials (n=930), one of which used the Oxford (Sharpe, 1991) case definition for inclusion.30 Decreased fatigue was found in four (n=807), including the Oxford based trial30and three fair quality CDC based trials.22, 23, 28, 34 The overall analyses of fatigue outcomes, including the single study using Oxford case definition inclusion criteria, provided low strength of evidence that CBT improves fatigue. In removing the Oxford case definition based study, we are left with four fair-quality studies, three finding benefit (n=327) and one finding no benefit (n=65), and one poor-quality study finding no benefit (n=58). The results are generally consistent with the overall conclusion and would provide low strength of evidence that CBT improves fatigue.

###### Quality of Life

Three trials assessed quality of life (n=325) and all fulfilled the CDC (Fukuda, 1994) case definition.24-28 Two of three trials assessing quality of life did not find a benefit with CBT. The one trial that found an improvement with CBT was a small (n=58) poor-quality study,27 which leads to a low strength of evidence that quality of life is not impacted by CBT.

###### Employment

Four trials, one with Oxford inclusion criteria (n=932) evaluated employment outcomes based on the work and social adjustment scale.20, 22-26, 30 Two trials (n=540), one Oxford based (n=480) and one CDC based (n=60),22, 23, 30 found significant improvement for CBT compared with controls while two CDC based trials (n=179), found no benefit. Based on these results, there is insufficient evidence to determine the effect of CBT on the outcome of work impairment whether the study using the Oxford definition is included or excluded. There is inconsistency between the mixed results of the three CDC based trials and the positive results of the one Oxford based trial.

###### Global Improvement

Two trials (n=540), one with Oxford inclusion criteria, evaluated global improvement and found benefit with CBT providing low strength of evidence that CBT benefits global improvement22, 23, 30 By excluding the study that used the Oxford case definition, there would be insufficient evidence to determine the effectiveness of CBT on the outcome of global improvement although the results of the single CDC based trial are consistent with the Oxford based trial.

##### Counseling and Other Behavioral Therapies

Two of the seven trials comparing counseling and other behavioral therapies with another intervention or a control used the Oxford (Sharpe, 1991) case definition (Table 3),31, 38-40 while the others used criteria that ultimately fulfilled the CDC (Fukuda, 1994) case definition (Table 4.^24-26, 32-37^

Table 3 Counseling and other behavioral therapy trials using Oxford case definition for inclusion

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Outcomes Reported | Benefit
Goudsmit, et al., 2009^31^ N=44 Poor | Oxford (Sharpe, 1991) criteria | 6 months | A. Counseling; B. Wait list | Fatigue, Function | Improved fatigue
Wearden, et al., 2010^38^ FINE Trial Wearden, et al., 2012^40^ Wearden, et al., 2013^39^ N=257 Good | Oxford (Sharpe,1991) criteria | 5 months (20 weeks) treatment; 17.5 months (70 weeks) total followup | A. Pragmatic rehab; B. Supportive listening; C. Usual care | Fatigue, Function, Harms | Improved short-term fatigue with pragmatic rehab No improvement at 70 weeks

Table 4 Counseling and other behavioral therapy trials using non-Oxford case definition for inclusion

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Outcomes Reported | Benefit
Jason, et al., 2007^26^ Jason, et al., 2009^25^ Hlavaty, et al., 2011^24^ N=114 Fair (also reported above) | CFS Questionnaire, psychiatric assessment for DSM-IV diagnosis, and medical assessment | 12 months | A. CBT; B. COG; C. ACT; D. Relaxation | Function, Fatigue, Quality of Life, Employment | Improved function with COG vs. ACT, p<0.01.
Jason, et al., 2010^32^ N=30 Poor | CDC (Fukuda, 1994) criteria | 4 months | A. Buddy counseling; B. Control, no treatment for 4 months | Function, Fatigue | Improved fatigue
Knoop, et al., 2008^33^ Tummers, et al., 2010^35^ N=169 Fair | CDC (Fukuda, 1994) criteria | 6-12 months depending on length of treatment | A. Self-instruction; B. Wait list control; Tummers, 2010; A. Stepped care; B. Usual care | Fatigue, Function | Improved fatigue and function with self-instruction
Taylor, 2004^34^ N=47 Good | CDC (Fukuda, 1994) criteria | 12 months | A. Counseling; B. Wait list | QOL, Harms | Improved QOL
Tummers, et al., 2012^36^ N=111 Good | CDC (Fukuda, 1994) criteria | 6 months | A. Self-instruction; B. Wait list | Fatigue, Function | Improved fatigue

Abbreviations: ACT=anaerobic activity therapy; CBT=cognitive behavioral therapy; CDC=Centers for Disease Control and Prevention; COG=cognitive therapy; QOL=quality of life; RCT=randomized controlled trial.

###### Function

Of the six trials evaluating measures of function (n=725), two used the Oxford (Sharpe, 1991) case definition for inclusion and both did not find improvement in function, n=301.^31, 38-40^ Of the four trials fulfilling the CDC (Fukuda, 1994) case definition, two found benefit (n=283),24-26,33,35 and two found no benefit (n=141).32,36 Four of the trials considered the SF-36 physical function subscale as the outcome measure (Figure 2). Of these, none found statistically significant benefit. Two of the other trials (n=183), one comparing self-instruction with wait list control and one comparing cognitive therapy with anaerobic activity therapy or relaxation, found improvement in measures of function.24-26, 33, 35 Overall, the analyses including the trials based on the Oxford (Sharpe, 1991) case definition provides low strength of evidence that counseling and other behavioral therapies do not improve function compared with controls. By excluding the Oxford case definition based trials, we are left with two trials finding benefit (n=283) and two trials, including one poor-quality trial, finding no benefit (n=141), which would provide insufficient evidence to determine the effectiveness of counseling and other behavioral therapies on the outcome of function. The CDC based results are mixed and thus inconsistent with the Oxford based studies, which found no improvement.

Figure 2 Effects of counseling therapies on physical function subscale of SF-36

* Therapy intended to change behavioral and belief factors that may trigger and maintain symptoms.

† vs. all controls from study combined.

‡ teaching of coping and self-sufficiency strategies.

§ strategies to promote a gradual progression of activity.

‖ listening therapy based on non-directive counseling.

¶ use of informative booklets with assignments

Abbreviations: CBT= cognitive behavioral therapy, CI= confidence interval, N=sample size, SD=standard deviation, SF-36=36-item Short Form Survey.

Figure 2 is a forest plot of 4 studies reporting weighted mean differences in chages on the SF-36 physical functioning subscale for counsling vs. behavioral therapies. Data for Figure 2 are presented in Tables 3 and 4. This figure is described further on pages 7 and 8 as follows: “Four of the trials considered the SF-36 physical function subscale as the outcome measure. Of these, none found statistically significant benefit. Two of the other trials (n=183), one comparing self-instruction with wait list control and one comparing cognitive therapy with anaerobic activity therapy or relaxation, found improvement in measures of function.”

###### Fatigue

Of the six trials evaluating outcomes of fatigue (n=725), two trials used the Oxford case definition for inclusion with one poor-quality trial (n=44) finding benefit31 and one good-quality trial finding short but not long term benefit (n=257).38-40 Fatigue was improved in three of the other trials of which one was of poor-quality (n=30),32 one was of fair-quality (n=114)33, 35 and one was of good-quality (n=111).36 Overall, this provides low strength of evidence that measures of fatigue improve with counseling and other behavioral therapies compared with control groups. Considering only the four trials that used the CDC based criteria for inclusion, three trials found benefit (n=310), and one trial found no benefit (n=114), which would provide low strength of evidence that counseling and other behavioral interventions improve the outcome of fatigue. The CDC based results are consistent with the Oxford based results demonstrating improvement in fatigue up to 6 months.

###### Quality of Life

Quality of life was evaluated in two trials using criteria that fulfilled the CDC (Fukuda, 1994) case definition for inclusion. One found no improvement with cognitive therapy (n=114) and one found improvement with counseling compared with a wait list control (n=47).34 This provides insufficient evidence that counseling and other behavioral therapies improves quality of life.

###### Employment and Global Improvement

Measure of employment was evaluated in one CDC based trial (n=114) with no improvement found when comparing cognitive therapy with anaerobic therapy or relaxation.24-26 No study evaluated the outcome of global improvement. There is insufficient evidence to determine the effectiveness of counseling or other behavioral therapies on the outcomes of employment or global improvement.

##### Summary

The body of evidence on counseling and behavioral therapy is evenly split in number of subjects from studies that used the Oxford (Sharpe, 1991) case definition (n=841) and studies that used the CDC (Fukuda, 1994) case definition (n=843).

In the CBT evidence, more subjects were enrolled in Oxford based studies then CDC based studies (n=983 vs. n=722). In considering the overall results including our meta-analysis of studies using SF-36 physical function outcomes in combination with the two other studies that assessed function using alternative measures of function, we are left with a low strength of evidence that CBT improves function. When we remove both studies that used the Oxford (Sharpe, 1991) case definition for inclusion, we are left with four trials with mixed results (n=392) which would provide insufficient evidence of the effect of CBT on the outcome of function. There is inconsistency between results from the CDC based trials and the Oxford based trials. For the outcome of fatigue, the overall results included a greater number of participants enrolled in the four trials that found benefit (n=807, including the Oxford based trial) compared with the two trials that found no benefit (n=123) providing a low strength of evidence for benefit with CBT. By removing the single Oxford based study, we found consistent results with three fair-quality trials finding benefit (n=327), one fair-quality trial finding no benefit (n=65), and one poor-quality trial finding no benefit (n=58) which would provide a low strength of evidence that CBT improves outcomes of fatigue. The conclusions for effect on quality of life has changed from a low strength of evidence of benefit when considering all counseling and behavioral interventions to low strength of evidence that CBT provides no benefit in quality of life based solely on studies that fulfilled a CDC (Fukuda, 1994) case definition for inclusion. There would be insufficient evidence on the effect of CBT on employment outcomes when considering all trials as well as when excluding the single study that used the Oxford (Sharpe, 1991) case definition for inclusion criteria. The CDC based trials had mixed results whereas the Oxford based trial had positive results. The strength of evidence on global improvement is downgraded from moderate to low when considering CBT separately from other counseling and behavioral interventions based on two trials, one Oxford based and one CDC based, both finding benefit. It would be further downgraded to insufficient when considering only the one small study that fulfilled CDC based criteria for inclusion (1trial, n=60).

When considering counseling and behavioral interventions other than CBT, two studies were Oxford based (n=301) and five were CDC based (n=471). Although there is enough variability amongst the other techniques that a meta-analysis might be inappropriate, all involve supportive guidance aimed at improving coping strategies and reducing impact of one's disease state on overall well-being justifying the decision to consider these together as a group. Although CBT is a unique approach with disputable underlying rationale regarding the fear avoidance theory contributing to the perpetuation of symptoms in ME/CFS, it has similar aims of improving coping strategies and improving overall well-being. We considered this as justification for our original approach of combining all interventions when determining the overall strength of evidence of this body of literature. By separating these interventions from CBT, and considering the overall results, there is low strength of evidence that counseling and other behavioral therapies excluding CBT provide improvement in fatigue, low strength of evidence for no improvement in outcomes of function, and insufficient strength of evidence for all other outcomes (Table 5). By removing the Oxford based studies, there would be a low strength of evidence that counseling and other behavioral therapies excluding CBT reduce fatigue (4 trials, n=424) with the mixed results being consistent with the results of the Oxford based trials. There would be insufficient evidence for all other outcomes. On the outcome of function there is inconsistency between the mixed results of the CDC based and the negative results of the Oxford based trials.

Table 5 CBT and other behavioral therapies strength of evidence

Outcome | Original Report (CBT + Counseling and Behavioral Therapies); All case definitions | CBT All Case Definitions | CBT Excluding Oxford Definition | CBT Direction of Effect using other^*^ Case Definition | CBT Direction of Effect using Oxford Case Definition | Other Therapies All Case Definitions | Other Therapies Excluding Oxford Definition | Other Therapies Direction of Effect using other^*^ Case Definition | Other Therapies Direction of Effect using Oxford Case Definition
Improved Function | Low | Low (6 trials, n=932) | Insufficient (4 trials, n=392) | ↑↓ | ↑ | Low (6 trials, n=725) | Insufficient (4 trials, n=424) | ↑↓ | –
Decreased Fatigue | Low | Low (6 trials, n=930) | Low (5 trials, n=443) | ↑ | ↑ | Low (6 trials, n=725) | Low (4 trials, n=424) | ↑ | ↑
Improved Quality of Life | Low | Low that quality of life is not impacted by CBT (3 trials, n=325) | Low strength of evidence that quality of life is not impacted by CBT (3 trials, n=325) | – | | Insufficient (2 trials, n=161) | Insufficient (2 trials, n=161) | ↑↓
Employment | Low for reduction in work impairment and increase in hours worked | Insufficient that CBT decreases work impairment (4 trials, n=932) | Insufficient (3 trials, n=239) | ↑↓ | ↑ | Insufficient (1 trial, n=114) | Insufficient (1 trial, n=114) | –
Global Improvement | Moderate for benefitting global improvement | Low (2 trials, n=531) | Insufficient (1 trial, n=60) | ↑ | ↑ | Insufficient 0 trials) | Insufficient (0 trials)

Abbreviations: CBT = cognitive behavioral therapy; CDC = Centers for Disease Control and Prevention

↑- benefit

↑↓- mixed

- no impact

* CDC (Schluederberg, 1992 or Fukuda 1994), OR CFS Questionnaire, psychiatric assessment for DSM-IV diagnosis, and medical assessment

#### Exercise Therapies

Six trials compared different forms of exercise therapy with control groups. Three trials used the Oxford (Sharpe, 1991) case definition for inclusion, all of which evaluated the effectiveness of graded exercise therapy (GET).12, 30, 41 Of the three trials using the CDC (Fukuda,1994) case definition, one trial evaluated the effectiveness of GET.42 The other two trials evaluated other exercise interventions and do not impact this addendum.43-45

##### Graded Exercise Therapy

Four trials evaluated the effectiveness of GET compared with a control group (n=656) (Table 6, Figures 3 and 4). Of these, three used the Oxford (Sharpe, 1991) case definition (n=607)12, 30, 41 while one small trial used the CDC (Fukuda, 1994) case definition (n=49).42 The results are consistent across trials with improvement in function, fatigue, and global improvement and provided moderate strength of evidence for improved function (4 trials, n=607) and global improvement (3 trials, n=539), low strength of evidence for reduced fatigue (4 trials, n=607) and decreased work impairment (1 trial, n=480), and insufficient evidence for improved quality of life (no trials) (Table 7). By excluding the three trials using the Oxford (Sharpe, 1991) case definition for inclusion, there would be insufficient evidence of the effectiveness of GET on any outcome (1 trial, n=49).

Table 6 Graded exercise therapy trials

Author, Year Study Type N Quality | Case Definition | Duration/Followup | Interventions | Outcomes Reported | Effectiveness
Oxford case definition for inclusion
Fulcher and White, 1997^41^ RCT N=59 Fair | Oxford (Sharpe, 1991) criteria | 3 months (12 weeks), 1 year followup | A. Exercise group; B. Control group | Function, Fatigue, Employment, CGI, Harms | Improved all outcomes Harms NS
Wearden, et al., 1998^12^ N=68 Fair | Oxford (Sharpe, 1991) criteria | 6.5 months (26 weeks) | A. GET; B. Placebo control* | Function, Fatigue, Harms | Improved fatigue and function; Greatest withdrawal with GET
White, et al., 2011^30^ PACE Trial N=480 Good Same study as on Table 1 | Oxford (Sharpe, 1991) criteria | 13 months (52 weeks) | A. GET; B. APT; C. Usual care† | Fatigue, function, employment, CGI, recovery; Harms | Improved all outcomes (CBT, GET) CBT vs. GET NS Most adverse events with GET
Non-Oxford case definition for inclusion
Moss-Morris, et al., 2005^42^ RCT N= 49 Fair | CDC (Fukuda, 1994) criteria | 3 months (12 weeks), 6 month follow-up | A. Exercise group; B. Control group | Function, Fatigue, Global Improvement | Improved function, fatigue and CGI 20% refused repeat exercise testing

Abbreviations: APT = adaptive pacing therapy; CBT = cogntive behavioral therapy; CGI = Clinical global impression change score; GET = graded exercise therapy; NS = not significant.

Figure 3 Graded exercise therapy effect on function

Abbreviations: CI = confidence interval; N = sample size; SD = standard deviation; SF-36 = 36-item Short Form Survey.

Figure 3 is a forest plot of 3 studies reporting the weighted mean differences in changes on the SF-36 physical functioning subscale for exercise versus controls. Data for Figure 3 are presented in Table 5. This figure is described further on page10 as follows: “The results are consistent across trials with improvement in function, fatigue, and global improvement.”

Figure 4 Graded exercise therapy effect on global improvement

Abbreviations: CI = confidence interval; N = sample size.

Figure 4 is a forest plot of 3 studies reporting improvement on the CGI for exercise versus controls. Data for Figure 4 are presented in Table 6. This figure is described further on page 10 as follows: “The results are consistent across trials with improvement in function, fatigue, and global improvement.”

Table 7 Graded exercise therapy strength of evidence

Outcome | Original Report | All Case Definitions | Excluding Oxford Definition | Direction of Effect Other^*^ Case Definition | Direction of Effect-Oxford Case Definition
Improved Function | Moderate | Moderate (4 trials, n=607 | Insufficient (1 trial, n=49) | ↑ | ↑
Decreased Fatigue | Low | Low (4 trials, n=607) | Insufficient (1 trial, n=49) | ↑ | ↑
Improved Quality of Life | Insufficient (0 trials) | Insufficient (0 trials) | Insufficient (0 trials)
Employment | Low for reduction in work impairment | Low (1 trial, n=480) | Insufficient (0 trials)
Employment | Low for increase hours worked | Insufficient (1 trial, n=59) | Insufficient (0 trials)
Global Improvement | Moderate | Moderate (3 trials, n=539) | Insufficient (1 trial, n=49) | ↑ | ↑

Abbreviations: CDC = Centers for Disease Control and Prevention

↑- benefit

* CDC (Fukuda 1994)

## Conclusions

Although future studies should refrain from using the Oxford (Sharpe, 1991) case definition as eligibility requirements, this early work provided a foundation on which future work can expand. This addendum has delineated differences in treatment effectiveness and harms according to case definitions, highlighting studies that used the Oxford (Sharpe, 1991) case definition and how these studies impacted our conclusions. Additionally, results of studies evaluating CBT have been considered independently from other counseling and behavioral therapies. Our sensitivity analysis would result in a downgrading of our strength of evidence on several outcomes which can be attributed to the decrease in power, dominance of one large trial, or lack of trials using criteria other than the Oxford (Sharpe, 1991) case definition for inclusion. Blatantly missing from this body of literature are trials evaluating effectiveness of interventions in the treatment of individuals meeting case definitions for ME or ME/CFS.

## References

1 Smith MEB, Nelson N, Haney E, et al. (2014). Diagnosis and treatment of myalgic encephalomyelitis/chronic fatigue syndrome (ME/CFS).
2 Green C, Cowan P, Elk R, et al. (2015). National Institutes of Health Pathways to Prevention Workshop: Advancing the Research on Myalgic Encephalomyelitis/Chronic Fatigue Syndrome. Ann Intern Med.
3 Committee on the Diagnostic Criteria for Myalgic Encephalomyelitis/Chronic Fatigue Syndrome, Board on the Health of Select Populations, Institute of Medicine. (2015). Beyond Myalgic Encephalomyelitis/Chronic Fatigue Syndrome Redefining an Illness.
4 Blacker CVR, Greenwood DT, Wesnes KA, et al. (2004). Effect of galantamine hydrobromide in chronic fatigue syndrome: a randomized controlled trial. JAMA.
5 Blockmans D, Persoons P, Van Houdenhove B, et al. (2003). Combination therapy with hydrocortisone and fludrocortisone does not improve symptoms in chronic fatigue syndrome: a randomized, placebo-controlled, double-blind, crossover study. Am J Med.
6 Diaz-Mitoma F, Turgonyi E, Kumar A, et al. (2003). Clinical improvement in chronic fatigue syndrome is associated with enhanced natural killer cell-mediated cytotoxicity: The results of a pilot study with Isoprinosine. J Chronic Fatigue Syndr.
7 McKenzie R, O'Fallon A, Dale J, et al. (1998). Low-dose hydrocortisone for treatment of chronic fatigue syndrome: a randomized controlled trial. JAMA.
8 Montoya JG, Kogelnik AM, Bhangoo M, et al. (2013). Randomized clinical trial to evaluate the efficacy and safety of valganciclovir in a subset of patients with chronic fatigue syndrome. J Med Virol.
9 Peterson PK, Shepard J, Macres M, et al. (1990). A controlled trial of intravenous immunoglobulin G in chronic fatigue syndrome. Am J Med.
10 Strayer DR, Carter WA, Brodsky I, et al. (1994). A controlled clinical trial with a specifically configured RNA drug, poly(I) midline dot poly(C12U), in chronic fatigue syndrome. Clin Infect Dis.
11 Strayer DR, Carter WA, Stouch BC, et al. (2012). A double-blind, placebo-controlled, randomized, clinical trial of the TLR-3 agonist rintatolimod in severe cases of chronic fatigue syndrome. PLoS ONE.
12 Wearden AJ, Morriss RK, Mullis R, et al. (1998). Randomised, double-blind, placebo-controlled treatment trial of fluoxetine and graded exercise for chronic fatigue syndrome. Br J Psychiatry.
13 Hobday RA, Thomas S, O'Donovan A, et al. (2008). Dietary intervention in chronic fatigue syndrome. J Hum Nutr Diet.
14 Öckerman PA. (2000). Antioxidant treatment of chronic fatigue syndrome. Clin Pract Alternat Med.
15 The GKH, Bleijenberg G, van der Meer JWM. (2007). The effect of acclydine in chronic fatigue syndrome: A randomized controlled trial. PLoS Clinical Trials.
16 Vermeulen RCW, Scholte HR. (2004). Exploratory open label, randomized study of acetyl- and propionylcarnitine in chronic fatigue syndrome. Psychosom Med.
17 Walach H, Bosch H, Lewith G, et al. (2008). Effectiveness of distant healing for patients with chronic fatigue syndrome: a randomised controlled partially blinded trial (EUHEALS). Psychother Psychosom.
18 Weatherley-Jones E, Nicholl JP, Thomas KJ, et al. (2004). A randomised, controlled, triple-blind trial of the efficacy of homeopathic treatment for chronic fatigue syndrome. J Psychosom Res.
19 Williams G, Waterhouse J, Mugarza J, et al. (2002). Therapy of circadian rhythm disorders in chronic fatigue syndrome: no symptomatic improvement with melatonin or phototherapy. Eur J Clin Invest.
20 Bazelmans E, Prins JB, Lulofs R, et al. (2005). Cognitive behaviour group therapy for chronic fatigue syndrome: a non-randomised waiting list controlled study. Psychother Psychosom.
21 Burgess M, Andiappan M, Chalder T. (2012). Cognitive behaviour therapy for chronic fatigue syndrome in adults: face to face versus telephone treatment: a randomized controlled trial. Behav Cogn Psychother.
22 Deale A, Chalder T, Marks I, et al. (1997). Cognitive behavior therapy for chronic fatigue syndrome: a randomized controlled trial. Am J Psychiatry.
23 Deale A, Husain K, Chalder T, et al. (2001). Long-term outcome of cognitive behavior therapy versus relaxation therapy for chronic fatigue syndrome: a 5-year follow-up study. Am J Psychiatry.
24 Hlavaty LE, Brown MM, Jason LA. (2011). The effect of homework compliance on treatment outcomes for participants with myalgic encephalomyelitis/chronic fatigue syndrome. Rehabil Psychol.
25 Jason L, Benton M, Torres-Harding S, et al. (2009). The impact of energy modulation on physical functioning and fatigue severity among patients with ME/CFS. Patient Educ Couns.
26 Jason LA, Torres-Harding S, Friedberg F, et al. (2007). Non-pharmacologic interventions for CFS: a randomized trial. J Clin Psychol Med Settings.
27 Lopez C, Antoni M, Penedo F, et al. (2011). A pilot study of cognitive behavioral stress management effects on stress, quality of life, and symptoms in persons with chronic fatigue syndrome. J Psychosom Res.
28 O'Dowd H, Gladwell P, Rogers CA, et al. (2006). Cognitive behavioural therapy in chronic fatigue syndrome: a randomised controlled trial of an outpatient group programme. Health Technol Assess.
29 Sharpe M, Hawton K, Simkin S, et al. (1996). Cognitive behaviour therapy for the chronic fatigue syndrome: a randomized controlled trial. BMJ.
30 White PD, Goldsmith KA, Johnson AL, et al. (2011). Comparison of adaptive pacing therapy, cognitive behaviour therapy, graded exercise therapy, and specialist medical care for chronic fatigue syndrome (PACE): a randomised trial. Lancet.
31 Goudsmit EM, Ho-Yen DO, Dancey CP. (2009). Learning to cope with chronic illness. Efficacy of a multi-component treatment for people with chronic fatigue syndrome. Patient Educ Couns.
32 Jason LA, Roesner N, Porter N, et al. (2010). Provision of social support to individuals with chronic fatigue syndrome. J Clin Psychol.
33 Knoop H, van der Meer JWM, Bleijenberg G. (2008). Guided self-instructions for people with chronic fatigue syndrome: randomised controlled trial. Br J Psychiatry.
34 Taylor RR. (2004). Quality of life and symptom severity for individuals with chronic fatigue syndrome: findings from a randomized clinical trial. Am J Occup Ther.
35 Tummers M, Knoop H, Bleijenberg G. (2010). Effectiveness of stepped care for chronic fatigue syndrome: a randomized noninferiority trial. J Consult Clin Psychol.
36 Tummers M, Knoop H, van Dam A, et al. (2012). Implementing a minimal intervention for chronic fatigue syndrome in a mental health centre: a randomized controlled trial. Psychol Med.
37 Tummers M, Knoop H, van Dam A, et al. (2013). Moderators of the treatment response to guided self-instruction for chronic fatigue syndrome. J Psychosom Res.
38 Wearden AJ, Dowrick C, Chew-Graham C, et al. (2010). Nurse led, home based self help treatment for patients in primary care with chronic fatigue syndrome: randomised controlled trial. BMJ.
39 Wearden AJ, Emsley R. (2013). Mediators of the effects on fatigue of pragmatic rehabilitation for chronic fatigue syndrome. J Consult Clin Psychol.
40 Wearden AJ, Dunn G, Dowrick C, et al. (2012). Depressive symptoms and pragmatic rehabilitation for chronic fatigue syndrome. Br J Psychiatry.
41 Fulcher KY, White PD. (1997). Randomised controlled trial of graded exercise in patients with the chronic fatigue syndrome. BMJ.
42 Moss-Morris R, Sharon C, Tobin R, et al. (2005). A randomized controlled graded exercise trial for chronic fatigue syndrome: outcomes and mechanisms of change. J Health Psychol.
43 Chan JSM, Ho RTH, Wang CW, et al. (2013). Effects of qigong exercise on fatigue, anxiety, and depressive symptoms of patients with chronic fatigue syndrome-like illness: A randomized controlled trial. Evidence based Complementary and Alternative Medicine.
44 Ho RTH, Chan JSM, Wang C-W, et al. (2012). A randomized controlled trial of qigong exercise on fatigue symptoms, functioning, and telomerase activity in persons with chronic fatigue or chronic fatigue syndrome. Ann Behav Med.
45 Sutcliffe K, Gray J, Tan MP, et al. (2010). Home orthostatic training in chronic fatigue syndrome--a randomized, placebo-controlled feasibility study. Eur J Clin Invest.