# Abbreviations and Acronyms

ACTH: adrenocorticotropic hormone
AHRQ: Agency for Healthcare Research and Quality
AUC: area under the curve
AUROC: area under the receiver operating characteristic
CAM: complementary and alternative medicine
CBT: cognitive behavioral therapies
CDC: Centers for Disease Control and Prevention
CFS: chronic fatigue syndrome
CGI: Clinical Global Impression Change
CI: confidence interval
CIS: Checklist of Individual Strength
CPET: Cardiopulmonary exercise test
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
FIQ: Fibromyalgia Impact Questionnaire
FIS: Fatigue Impact Scale
FLP: Functional Limitations Profile
FSS: Fatigue Severity Scale
GET: graded exercise treatment
HADS: Hospital Anxiety and Depression Scale
HADS-A: anxiety subscale of HADS
HADS-D: depression subscale of HADS
HR: hazard ratio
IGF-1: insulin-like growth factor one
KPS: Karnofsky Performance Scale
ME: myalgic encephalomyelitis
MFI-20: Multidimensional Fatigue Inventory, 20-item
MOS-SF: Medical Outcome Study Short Form
NIH: National Institutes of Health
ODP: Office of Disease Prevention
OR: odds ratio
PEM: post exertional malaise
PICOTS: populations, interventions, comparators, outcomes, timing, setting
POMS: Profile of Mood States
QLI: Quality of Life Index
QLS: Quality of Life Scale
QOLI: Quality of Life Inventory
RA: rheumatoid arthritis
ROC: receiver operating curve
RR: relative risk
SCL-90-R: Symptom Checklist-90-revised
SD: standard deviation
SF-12: Short Form 12-item Health Survey
SF-36: 36-item Short Form Survey
SIP-8: Sickness Impact Profile 8-item
TEP: technical expert panel
TSST: Trier Social Stress Test
VAS: visual analog scale