# Results

## Overview

The search and selection of articles are summarized in the study flow diagram (Figure 2). Database searches resulted in 4,209 potentially relevant articles. After dual review of abstracts and titles, 667 articles were selected for full-text review, and 39 studies (in 40 publications) were determined by dual review at the full-text level to meet inclusion criteria and were included in this review. Data extraction and quality assessment tables for all included studies per Key Question are available in Appendixes E and F.

Figure 2 Literature flow diagram

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trails and the Cochrane Database of Systematic Reviews.

^b^ Other sources include reference lists of relevant articles, systematic reviews, etc.

^c^ Some studies have multiple publications, and some are included for more than one Key Question.

This figure is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 4,209 abstracts of potentially relevant articles were identified through MEDLINE, Cochrane, PsychINFO, CINAHL, and other sources, while 667 articles were reviewed at the full-text level after excluding 3,542 non-relevant abstracts and background articles. From the 667 articles reviewed for inclusion, 627 were excluded due to wrong population (158), wrong intervention (63), wrong outcomes (20), wrong comparator (31), wrong study design (98), wrong publication type (54), inadequate duration (168), or being a systematic review or meta-analysis used only as a source document (35). After excluding these studies, 39 studies in 40 publications were included that provide evidence for any of the four Key Questions. The following numbers of studies were included: 18 studies (in 19 publications) for Key Question 2a, 7 studies for Key Question 2b, 3 studies (in 2 publications) for Key Question 3a, 5 studies for Key Question 3c, 1 study for Key Question 3f, 5 studies for Key Question 3h, 1 study for Key Question 3i, 2 studies for Key Question 3j, and 4 studies for Key Question 4a. No studies were included for Key Questions 1a-d, 3b, 3d-e, 3g, or 4b-d.

## Key Question 1a In patients with chronic pain, what is the effectiveness of long-term opioid therapy versus placebo or no opioid therapy for long-term (≥1 year) outcomes related to pain, function, and quality of life?

### Key Points

- No study of opioid therapy versus placebo or no opioid therapy evaluated long-term (≥1 year) outcomes related to pain, function, or quality of life (SOE: Insufficient).

### Detailed Synthesis

All studies in the 2009 APS review evaluated outcomes related to pain, function, and quality of life at less than 1 year (typically at ≤12 weeks) and did not meet inclusion criteria for the current review. We also identified no studies published since the 2009 APS review that met inclusion criteria. Although a systematic review8 of long-term opioid therapy included 10 studies of oral opioids and five studies of transdermal opioids that evaluated outcomes after at least 6 months, all were case series or uncontrolled long-term continuations of patients enrolled in clinical trials, with the exception of one head-to-head randomized trial that compared two long-acting opioids (see Key Question 3c).43 In the systematic review, the pooled estimate for discontinuation due to insufficient pain relief was 10.3 percent (95 percent CI 7.6 to 13.9 percent) with oral opioids and 5.8 percent (95 percent CI 4.2 to 7.9) with transdermal opioids. Among patients who remained on oral opioids for at least 6 months, pain scores were generally reduced, but estimates varied substantially. Effects on quality of life and functional status were inconclusive. Findings of this review are difficult to interpret due to the lack of a nonopioid comparison group in the included studies, marked statistical heterogeneity, and other methodological shortcomings of the studies.

## Key Question 1b How does effectiveness vary depending on: (1) the specific type or cause of pain (e.g., neuropathic, musculoskeletal [including low back pain], fibromyalgia, sickle cell disease, inflammatory pain, and headache disorders); (2) patient demographics (e.g., age, race, ethnicity, gender); (3) patient comorbidities (including past or current alcohol or substance use disorders, mental health disorders, medical comorbidities and high risk for addiction)?

### Key Points

- No study met inclusion criteria (see Key Question 1a) (SOE: Insufficient).

### Detailed Synthesis

No study met inclusion criteria (see Key Question 1a). Although one systematic review44 reported similar short-term effects of opioids versus placebo on improvement in pain scores for nociceptive (31 studies) and neuropathic (13 studies) pain, the studies included in the review did not meet inclusion criteria due to the short duration of followup. In the review, 61 of 62 included randomized trials were 16 weeks or shorter in duration, and the other trial was 24 weeks. There were too few trials of fibromyalgia (two studies) or mixed pain conditions (one study) to reliably estimate effects of opioids for these pain conditions.

## Key Question 1c In patients with chronic pain, what is the comparative effectiveness of opioids versus nonopioid therapies (pharmacological or nonpharmacological) on outcomes related to pain, function, and quality of life?

### Key Points

- No study met inclusion criteria (SOE: Insufficient).

### Detailed Synthesis

We identified no study on the comparative effectiveness of long-term opioid therapy versus nonopioid therapies on long-term outcomes related to pain, function, and quality of life.

## Key Question 1d In patients with chronic pain, what is the comparative effectiveness of opioids plus nonopioid interventions (pharmacological or nonpharmacological) versus opioids or nonopioid interventions alone on outcomes related to pain, function, quality of life, and doses of opioids used?

### Key Points

- No study met inclusion criteria (SOE: Insufficient).

### Detailed Synthesis

We identified no study on the comparative effectiveness of long-term opioid therapy plus nonopioid interventions versus opioids or nonopioid interventions alone on long-term outcomes related to pain, function, and quality of life.

## Key Question 2a In patients with chronic pain, what are the risks of opioids versus placebo or no opioid on: (1) opioid abuse, addiction, and related outcomes; (2) overdose; and (3) other harms, including gastrointestinal-related harms, falls, fractures, motor vehicle accidents, endocrinological harms, infections, cardiovascular events, cognitive harms, and psychological harms (e.g., depression)?

### Key Points

- One fair-quality retrospective review of a large database of claims from commercial health plans found long-term (≥91 days supply) prescribed opioid use associated with significantly increased risk of opioid abuse or dependence diagnosis versus no opioid use (1-36 MED/day: OR 15, 95 percent CI 10 to 21; 36-120 MED/day: OR 29, 95 percent CI 20 to 41; ≥120 MED/day: OR 122, 95 percent CI 73 to 206) (SOE: Low).
- In 10 uncontrolled studies, estimates of opioid abuse, addiction, and related outcomes varied substantially even after stratification by clinic setting. Rates of diagnosed opioid abuse were 0.6 percent to 8 percent and rates of dependence were 3 percent to 26 percent in primary care settings. In pain clinic settings, rates of misuse were 8 to 16 percent and addiction 2 to 14 percent, but studies varied in methods used to define and ascertain outcomes. Rates of (variably-defined) aberrant drug-related behaviors (e.g., positive urine drug tests, medication agreement violations) ranged from 5.7 percent to 37.1 percent (SOE: Insufficient).
- One fair-quality retrospective cohort study found recent opioid use to be associated with increased risk of any overdose events (adjusted hazard ratio [HR] 5.2, 95 percent CI 2.1 to 12) and serious overdose events (adjusted HR 8.4, 95 percent CI 2.5 to 28) versus current nonuse in chronic pain patients who had received opioids at some point (SOE: Low).
- One fair-quality cohort study and one good-quality case-control study found use of opioids to be associated with increased risk of fracture (adjusted HR 1.28, 95 percent CI 0.99 to 1.64 and adjusted OR 1.27, 95 percent CI 1.21 to 1.33) though the estimate was not statistically significant in the cohort study and the risk was no longer present with more than 20 cumulative prescriptions in the other (SOE: Low).
- One good-quality case-control study found current opioid use versus nonuse to be associated with increased risk of myocardial infarction (adjusted OR 1.28, 95 percent CI 1.19 to 1.37). The risk was highest with 11 to 50 cumulative prescriptions (OR 1.3 8, 95 percent CI 1.28 to 1.49). A fair-quality cohort study found chronic opioid therapy, compared to the general population, to be associated with increased risk of myocardial infarction (adjusted incidence rate ratio [IRR] 2.66, 95 percent CI 2.30 to 3.08) and of myocardial infarction or revascularization (adjusted IRR 2.38, 95 percent CI 2.15 to 2.63) (SOE: Low).
- One fair-quality cross-sectional study of men with back pain (n=11,327) found long-term opioid use versus nonuse of opioids to be associated with increased risk for use of medications for erectile dysfunction or testosterone replacement (adjusted OR 1.5, 95 percent CI 1.1 to 1.9) (SOE: Low)
- No study evaluated the association between long-term opioid therapy for chronic pain versus no opioid therapy and risk of motor vehicle accidents, infections, psychological harms, or cognitive harms.

### Detailed Synthesis

#### Opioid Abuse, Addiction, and Related Outcomes

The 2009 APS review included two systematic reviews on use of opioids for chronic pain and rates of opioid abuse, addiction, or related outcomes.45, 46 One systematic review that restricted inclusion to studies with at least 1 year of followup reported signs of opioid addiction in 0.27 percent of patients prescribed opioids in studies that reported this outcome.45 However, none of the studies met inclusion criteria for the current review because addiction was not the primary outcome and they did not describe pre-specified methods for defining or ascertaining these outcomes. The other systematic review focused on patients with low back pain and reported rates of aberrant medication-taking behaviors that ranged from 5 to 24 percent.46 The studies did not meet inclusion criteria for the current review because they did not include patients with at least 1 year of followup, did not clearly separate abuse and addiction related to opioid use versus other substances, or did not report pre-specified methods for the outcomes, with the exception of one retrospective cohort study.47 It reported rates of opioid abuse behaviors in patients with chronic pain in primary care settings, based on chart review findings of one or more reports of lost or stolen opioid medications, documented use of other sources to obtain opioid medications, or requests for two or more early refills. Rates of opioid abuse behaviors were 24 percent (12/50) in a VA primary care setting and 31 percent (15/48) in a non-VA, urban hospital- based primary care setting. Factors associated with decreased risk of opioid abuse behaviors were no history of substance use disorder (adjusted OR 0.72, 95 percent CI 0.45 to 1.1) and older age (adjusted OR 0.94, 95 percent CI 0.94 to 0.99).

We identified no randomized trial published since the APS review on risk of opioid abuse, addiction, and related outcomes in patients with chronic pain prescribed long-term opioid therapy. One fair-quality retrospective study of patients in a large administrative database newly diagnosed with chronic (non-cancer) pain and followed for 18 months found prescribed long- term opioid use (receipt of ≥91 days’ supply of opioids within a 12-month period), versus no prescribed opioids, associated with increased risk of opioid use disorder (defined as opioid abuse and dependence based on ICD-9 codes) (Appendix E1 and F1).48 Rates of opioid abuse or dependence were 0.72, 1.28 and 6.1 percent in those prescribed low (1-36 mg MED/day), medium (36-120 mg MED/day) and high (≥120 mg MED/day) opioid doses, respectively, during the 12 months after the new chronic pain diagnosis, versus 0.004 percent in those with no opioid prescription. Compared to no opioid prescription and after adjustment for age, sex, history of substance abuse/dependence diagnosis and other comorbidities, chronic opioid use was associated with significantly increased risk of abuse or dependence for all doses of opioids (low dose: OR 15, 95 percent CI 10 to 21; medium dose: OR 29, 95 percent CI 20 to 41; high dose: OR 122, 95 percent CI 73 to 206).

Ten additional uncontrolled studies (in 11 publications) of patients with chronic pain, the majority of whom were prescribed opioids for at least 1 year, evaluated abuse and related outcomes as a primary outcome using explicit, predefined criteria (Table 1 below; Appendix E1 and F2).49-58 All were rated fair-quality; none of the studies reported blinding of outcome assessors to patient characteristics, such as risk factors for substance abuse or psychological comorbidities. Another shortcoming in some studies was failure to assess the predefined outcomes in all patients.

Table 1 Uncontrolled studies of long-term opioid use and abuse, misuse, and related outcomes

Author, Year Duration, If Applicable | Sample Characteristics Opioid Dose, Opioid Duration, and Pain Type | Method of Ascertaining and Defining Abuse/Misuse | Main Results
Banta-Green, 2009^49^ Cross-sectional | n=704 Integrated group practice patients in a nonprofit healthcare system in Washington State Mean age: 55 years Female sex: 62% Race: 89% non-Hispanic White Dose: mean 50 mg/day MED, past year Duration: NR Pain type: NR | Composite International Diagnostic Interview (CIDI) for DSM-IV opioid diagnoses | Opioid dependence: 13% (91/704) Opioid abuse without dependence: 8% (56/704)
Boscarino, 2010^50^ Cross-sectional | n=705 Primary and specialty care patients in integrated healthcare system in Pennsylvania who received 4+ opioid prescriptions in past 12 months Age: 18-64 years: 79% 65+ years: 21 % Female sex: 61 % White race: 98% Dose: NR Duration: mean of 10.7 opioid prescriptions over 1 year Pain type: non-cancer, otherwise not described | Composite International Diagnostic Interview (CIDI) for DSM-IV criteria for opioid dependence UDT: not examined | 25.8% (95% CI: 22.0-29.9) met criteria for current opioid dependence; 35.5% (95% CI: 31.1-40.2) met criteria for lifetime dependence Factors associated with current dependence: Age <65 years (OR 2.3, 95% CI 1.6 to 3.5) History of opioid abuse (OR 3.8, 95% CI 2.6 to 5.7) History of high dependence severity (OR 1.9, 95% CI 1.4 to 2.5) History of major depression (OR 1.3, 95% CI 1.1 to 1.6) Current use of psychotropic medications (OR 1.7, 95% CI 1.2 to 2.5)
Carrington Reid, 2002^47^ Retrospective cohort | n=98 (50 at VA and 48 at urban primary care clinic) patients with 6+ months of opioid prescriptions during 1 year VA primary care clinic vs. urban hospital primary care clinic Median age: 54 vs. 55 years Female sex: 8% vs. 67% Race: 88% White, 12% Black vs. 52% White, 36% Black, 10% Hispanic Median duration of pain: 10 vs. 13 years Dose: NR Duration: 6+ months of opioid prescriptions during past year Pain type: Non-cancer, Various (low back 44% vs 25%) | Chart review for reports of lost or stolen opioids, documented use of other sources to obtain opioids, and requests for ≥2 early refills UDT: not examined | VA site vs. urban primary care site Opioid abuse behaviors: 24% (12/50) vs. 31% (15/48) Median time to onset of abuse behaviors: 24 months Factors associated with odds of opioid abuse behaviors: History of substance use disorder (adjusted OR 3.8, 95% CI 1.4 to 10.8) Age (adjusted OR 0.4, 95% CI 0.9 to 1.0) Number of medical diseases (adjusted OR 0.7, 95% CI 0.5-1.1)
Compton, 2008^51^ 1 year | n=135 veterans at a VA pain clinic Mean age: 53 years Female sex: 6% Race: NR Baseline mean usual pain VAS (0-10) rating: 6.75 Dose: NR Duration: NR Pain type: 77% musculoskeletal, 19% neuropathic, 4% multi-category | Chart review for opioid discontinuation due to medication agreement violation (including for opioid misuse or abuse) UDT: not examined | Discontinuation due to medication agreement violation: 28% (38/135) Discontinuation due to specific problematic opioid misuse behaviors: 8% (11/135)
Cowan, 2003^52^ Cross-sectional | n=104 patients who had been prescribed opioids at a pain clinic in a UK NHS hospital Mean age: 55.4 years Female sex: 39% Race: NR Mean duration of pain: 10.5 years Dose: NR Duration: mean 14.1 months; 57% of the 104 patients had permanently stopped opioid therapy Pain type: 34% degenerative disease other than OA, 24% failed back/neck surgery syndrome, 10% complex regional pain syndrome, 10% osteoarthritis | SUQ UDT: not examined | Self-reported addiction: 1.9% (2/104) Craving opioids: 2.9% (3/104) Has taken drugs to enhance the effect of opioids: 0.9% (1/104) Has used alcohol to enhance the effect of opioids: 0.9% (1/104)
Fleming, 2007^53^ See also: Saffier, 2007^56^ Cross-sectional | n=801 primary care patients on daily opioid therapy Mean age: 48.6 years Female sex: 68% Race: 75.6% White; 23.1 % African American; 1 % other Disability income: 48% Mean daily dose: 92 mg MED Duration: 96% prescribed COT for ≥12 mos. Pain type: Degenerative aarthritis: 24%; low back pain: 21%; migraine headache 8%; neuropathy 5.5% | In-person interviews with Addiction Severity Index (ASI); Substance Dependence Severity Scale (SDSS); Aberrant Behavior 12-item List UDT: sample collected at end of interview | Met DSM-IV criteria for opioid dependence: 3.1 % Met DSM-IV criteria for opioid abuse: 0.6% Any illicit drug on UDT: 24% (mostly marijuana) Purposely over-sedated: 24% (186/785) Felt intoxicated from pain medication: 33% (260/785) Requested early refills: 45% (359/785) Increased dose on own: 37% (288/785) Medications lost or stolen: 30% (236/785) Used opioid for purpose other than pain: 16% (125/785) Drank alcohol to relieve pain: 20% (154/785)
Hojsted, 2010^54^ Cross-sectional | n=253 patients at a pain clinic (236 non-cancer and 17 cancer pain) Mean age: 52 years Female sex: 64% Race: NR Receiving opioids: 74% (187/253) Dose: Median daily dose = 90 mg MED among those taking opioids Duration: mean 6.8 years among those taking opioids who returned a questionnaire Pain type: 28% nociceptive pain, 33% neuropathic pain, 39% mixed nociceptive and neuropathic | Addiction screening by physician and nurse (blinded to each other) using the ICD-10 and Portenoy's Criteria; a positive screen by either provider was considered positive UDT: not examined | Addiction to opioids or hypnotics, ICD-10: total sample 11 % (28/253); among those taking addictive drugs 13%; among those taking opioids 14% Addiction to opioids, ICD-10, among those taking opioids: 14.4% (27/187) Addiction to opioids or hypnotics, Portenoy's Criteria. among those taking opioids: 19% (36/187) Addiction to opioids, Portenoy's Criteria: 19% (36/187)
Portenoy, 2007^55^ 3 years | n=227 patients enrolled in a registry study of patients who had participated in a previous controlled clinical trial of CR oxycodone for noncancer pain and who continued to take CR oxycodone Mean age: 56 years Female sex: 57% Race: 90% White BPI average pain score: 6.4 Dose: mean 52.5 mg MED/day Duration: mean 541 days Pain type: 38% osteoarthritis pain, 31% diabetic neuropathy, 31 % low back pain | Physician-completed brief questionnaire assessing problematic drug-related behavior with verification by an independent panel of experts UDT: not examined | Problematic drug-related behavior identified by physicians: 5.7% (13/227) Problematic drug-related behavior adjudicated by expert panel as meeting DSM-IV criteria for drug abuse or dependence: 0 Problematic drug-related behavior adjudicated by expert panel as positive: 2.2% (5/227) Problematic drug-related behavior adjudicated by expert panel as possible: 0.4% (1/227) Problematic drug-related behavior adjudicated by expert panel as withdrawal but no indication of abuse: 0.4% (1/227) Problematic drug-related behavior adjudicated by expert panel as suspected abuse/dependence but insufficient information to draw definitive conclusion: 2.2% (5/227) Problematic drug-related behavior adjudicated by expert panel as no evidence of abuse, dependence, or euphoria: 0.4% (1/227) Overdose deaths: 1 (phenylpropanolamine, oxycodone, and alcohol)
Schneider, 2010^57^ Retrospective chart review | n=197 patients treated by a pain specialist for at least one year Mean age: 49 years Female sex: 67% Race: NR Dose: mean 180 mg/day MED (long-acting), 49 mg/day MED (short-acting) Duration: mean 4.7 years Pain type: 51 % back pain, 10% neck pain, 9% fibromyalgia, 8% other myofascial pain | UDT: immunoassay followed by confirmatory GC/MS | Positive UDT: 8.7% (14/161) Aberrant drug-related behaviors noted in chart: 15.7% (31/197)
Wasan, 2009^58^ Cross-sectional | n=622 chronic noncancer pain patients from pain management centers on long-term opioid therapy Mean age: 50.4 years Female sex: 55% Race: 80% White Mean pain rating (0-10): 5.96 Dose: NR Duration: mean 6.2 years Pain type: 61% low back pain | POTQ, PDUQ, and UDT (immunoassay and confirmatory GCMS) | Positive scores of ≥2 on POTQ: 24% (115/480) Score ≥11 on PDUQ: 29.1 % (130/447) Positive UDT: 37.1 % (134/356)

Abbreviations: ASI= Addiction Severity Index, CI=confidence interval, CIDI=Composite International Diagnostic Interview, DSM-IV= Diagnostic and Statistical Manual Fifth Edition, GC/MS=gas chromatography mass spectrometry, ICD-10=International Statistical Classification of Diseases and Related Health Problems Version 10, MED=morphine-equivalent dose, NA=not applicable, NR= not reported, OR=odds ratio, PDUQ=Prescription Drug Use Questionnaire, POTQ=Prescription Opioid Therapy Questionnaire, SDSS=Dependence Severity Scale, SUQ=Self-report Substance Use Questionnaire, UDT=urine drug test, VA=Veterans Affairs.

Four of the new studies were performed exclusively or primarily in U.S. primary care settings.47, 49, 50, 53 One study53 found that 0.6 percent of primary care clinic patients receiving daily prescription opioids (96 percent for more than a year; total n=801) met the Diagnostic and Statistical Manual of Mental Disorders Fourth Edition (DSM-IV) criteria for opioid abuse disorder and 3.1 percent for opioid dependence, based on formal diagnostic interviews. Behaviors indicative of opioid misuse were more common. Thirty-seven percent reported increasing doses on their own, 33 percent feeling intoxicated from pain medication, 24 percent purposeful over-sedation, 16 percent using opioids for purposes other than pain management, and 20 percent drinking alcohol to relieve pain. Twenty-four percent of patients had urine drug screens positive for illicit drugs (mostly cannabinoids).53 A retrospective study of chronic pain patients receiving long-term opioid therapy in an integrated managed care health system (n=704) found that 13 percent met DSM-IV criteria for opioid dependence and 8 percent met criteria for opioid abuse without dependence, based on structured phone interviews.49 Another study, which performed diagnostic interviews in 9 primary care and 3 specialty clinics with patients who received 4 or more opioid prescriptions over a year (n=705), found that 26 percent met DSM-IV criteria for current opioid dependence.50 In multivariate logistic regression models, factors associated with current opioid dependence were age less than 65 years (OR 2.3, 95 percent CI 1.6 to 3.5), history of opioid abuse (OR 3.8, 95 percent CI 2.6 to 5.7), higher lifetime opioid dependence severity (OR 1.9, 95 percent CI 1.4 to 2.5), history of major depression (OR 1.3, 95 percent CI 1.1 to 1.6), and current use of psychotropic medications (OR 1.7, 95 percent CI 1.2 to 2.5). Rates of opioid abuse or misuse behaviors were not reported.

Six other studies were performed in pain clinic settings. Pain clinics may have a higher proportion of patients with opioid abuse and related problems because of referral patterns. Despite initial screening to exclude current substance abuse on entry, one study from a VA pain clinic found that after 1 year of followup, 28 percent of patients prescribed opioids (n=135) were discontinued from the clinic because of medication agreement violations.51 Among these were 8 percent with specific opioid misuse behaviors such as unsanctioned dose increases or use of opioids other than those prescribed. In a cross-sectional study of Danish pain clinic patients with cancer and noncancer pain (mean duration of opioid use among those taking opioids = 6.8 years), 14.4 percent of those using opioids (n=187) met International Classification of Diseases (ICD-10) criteria for “addiction to opioids,” which correspond most closely to the DSM-IV criteria for opioid abuse.54 A cross-sectional study of UK NHS hospital pain clinic patients who had been prescribed opioids (n=104) found that 1.9 percent of the patients self-reported addiction using the Substance Use Questionnaire, 2.9 percent reported that they had craved opioids and 0.9 percent reported that they used alcohol to enhance the effects of opioids.52 A prospective registry study of patients who had participated in five clinical trials of CR oxycodone and who continued to take this medication (n=227) found that 5.7 percent of the patients were identified by their physicians as exhibiting problematic drug-related behaviors, based on a brief physician- completed questionnaire.55 However, verification by an independent panel resulted in a lower rate of 2.2 percent. A chart review conducted in a single pain clinic (n=197) reported that 15.7 percent of patients had aberrant drug-related behaviors noted in their charts and 8.7 percent had positive urine drug tests.57 Finally, a cross-sectional study of patients attending five pain clinics (n=622) 0 found that 37.1 percent had positive urine drug tests (defined as presence of an illicit substance or unprescribed opioid), while 24 percent had positive scores ≥2 (the cutoff for “high risk”) on the Prescription Opioid Therapy Questionnaire and 29.1 percent had scores ≥11 (the cutoff for “at risk”) on the Prescription Drug Use Questionnaire.58

A challenge in interpreting the evidence on rates of opioid abuse, addiction, and related outcomes is inconsistency in how these outcomes were defined, as well as variability in methods used to ascertain these outcomes. In addition, definitions and usage of these terms have changed over time. The studies described above were all conducted prior to the American Psychiatric Association’s new DSM-V59 diagnostic criteria for current opioid use disorder.

Overall, because of methodological limitations in the available studies and because estimates for opioid abuse, addiction, and related outcomes were highly variable even after stratifying by clinical setting, the SOE was rated Insufficient.

#### Overdose

The 2009 APS review identified no studies on the risk of overdose in patients with chronic pain prescribed long-term opioid therapy versus placebo or no opioid. Epidemiological studies that reported opioid-related deaths did not have a nonopioid control group, did not have denominators for the numbers of people prescribed opioids, were not designed to distinguish deaths related to prescribed opioids from deaths related to illicit use of opioids, or did not focus on patients on long-term opioid therapy.60

We identified one fair-quality retrospective cohort study published since the APS review that reported risk of overdose with opioid use versus nonuse in patients (n=9,940) in a U.S. integrated health care system with a new episode of opioid use (defined as no opioid prescription in the past 6 months), a chronic noncancer pain diagnosis within 2 weeks before the initial opioid prescription, and at least 3 opioid prescriptions in the first 90 days of the episode (Appendix E2 and F1).61 The mean duration of followup was 42 months, and short-acting opioids were the most frequently prescribed type; only 10 percent of the patients received predominantly long- acting opioids. Overdoses were identified through ICD-9 codes and a State mortality registry, with verification through medical record review. Risk estimates were based on recently dispensed opioids at the time of the overdose event. Therefore, results may be interpreted as risk of overdose with current use versus nonuse in people previously prescribed opioid therapy for several months.

The annual overdose rate was 256 per 100,000 person-years in patients who recently received prescribed opioids versus 36 per 100,000 person-years in people who did not. After adjustment for smoking, depression, substance abuse, comorbid conditions, pain site, age, sex, recent sedative-hypnotic prescription, and recent initiation of opioid use, recent receipt of any prescribed opioids, compared to no opioid receipt, was associated with increased risk of any overdose events (HR 5.2, 95 percent CI 2.1 to 12.5) and serious overdose events (HR 8.4, 95 percent CI 2.5 to 28) (SOE: Low).

#### Gastrointestinal Harms

The APS review identified no studies on risk of gastrointestinal harms with long-term opioid therapy versus placebo or nonuse, and we identified no studies published since the APS review meeting inclusion criteria. Systematic reviews included in the APS review were based on short- term trials that reported frequent nausea, constipation, and vomiting in patients prescribed opioids.22, 62, 63

#### Fractures

The APS review included a systematic review of six observational studies of the association between opioid use and fracture. All six studies reported a statistically significant association, with a pooled RR of 1.38 (95 percent CI 1.15 to 1.66).64 The APS review also included a case- control study not in the systematic review that also found use of various opioids to be associated with increased risk of fracture (OR estimates ranged from 1.1 to 2.2).65 However, none of these studies meet inclusion criteria for the current review, because they did not specifically evaluate patients with chronic pain or on long-term opioid therapy. In addition, the studies had important methodological limitations, including failure to adjust for important confounders. Other studies published since the 2009 APS review also evaluated the association between opioid use and fractures, but did not meet inclusion criteria for similar reasons.66-70

We identified one cohort study18 and one case-control study71 published since the APS review on the association between opioid use and fracture in patients with chronic pain or on long-term opioid therapy (Appendix E3, F1, and F3). The cohort study identified patients 60 years and older with a diagnosis of noncancer pain initiating a new episode of opioid use (no opioid prescription fills in the prior 6 months) who had at least three opioid prescriptions in the first 90 days of the episode.18 Patients were followed for a mean of 33 months. The overall annual confirmed nonvertebral fracture rate was 5 percent (6 percent among current opioid users and 4 percent among people not currently using opioids; HR 1.28, 95 percent CI 0.99 to 1.64, adjusted for demographic factors, prior fractures, comorbidities, and concomitant medication use). The most commonly prescribed opioids were hydrocodone (42 percent), oxycodone (24 percent), and codeine combinations (14 percent). The study was rated fair-quality due to failure to report loss to followup and unclear blinding of outcomes assessors.

One good-quality case-control study evaluated 21,739 people with hip, humerus, or wrist fractures from the UK General Practice Research Database and 85,326 nonfracture controls matched on age, sex, date of fracture diagnosis, and practice site.71 Although the study did not specifically focus on patients with chronic pain, the analysis was stratified by duration of opioid use, based on the cumulative number of opioid prescriptions before the index date. After adjustment for a number of factors, including smoking status, comorbidities, concomitant medications, type of pain, and recent or past opioid use, current opioid therapy was associated with increased risk of fracture versus nonuse (OR 1.27, 95 percent CI 1.21 to 1.33). The risk was highest with one prescription (OR 2.70, 95 percent CI 2.34 to 3.13) and decreased with higher numbers of prescriptions, with no increased risk for patients with more than 20 cumulative prescriptions, suggesting that increased risk of fracture may be associated with more recent initiation of opioid therapy.

The SOE for the association between opioid use versus non-use and risk of fractures was rated Low.

#### Motor Vehicle Accidents

The APS review included two systematic reviews72, 73 (25 and 48 observational studies) and five other observational studies74-78 on the association between opioid use and driving safety, but none of the studies met inclusion criteria for the current review because they did not report duration of opioid use, included individuals treated for opioid addiction or using opioids illicitly, focused on surrogate markers of driving safety such as simulated driving tests or measures of cognitive performance rather than actual motor vehicle accidents, or did not include a comparison arm of chronic pain patients not prescribed opioids. We identified no studies published since the APS review on risk of motor vehicle accidents in patients with chronic pain on long-term opioid therapy versus no opioid therapy.

#### Cardiovascular Events

The APS review did not evaluate the association between opioid therapy for chronic pain and risk of cardiovascular events. We identified one cohort study79 and one case-control study80 on the association between long-term opioid use for chronic pain and risk of myocardial infarction (Appendix E4, F2, and F3). The cohort study included individuals with claims for opioids or a nonselective cyclo-oxygenase-2 (COX-2) inhibitor over a cumulative period of ≥180 days over a 3.5 year period.79 Individuals were excluded if they had cancer pain or a history of myocardial infarction or cancer and were matched on age, sex and cohort entry date to people in the general population who did not receive ≥180 days of opioids or COX-2 selective non-steroidal anti- inflammatory drugs (NSAIDs). Compared to the general population, chronic opioid therapy was associated with increased risk of myocardial infarction (adjusted IRR 2.66, 95 percent CI 2.30 to 3.08) and of myocardial infarction or revascularization (adjusted IRR 2.38, 95 percent CI 2.15 to 2.63), after controlling for age, sex, cardiovascular and other comorbidities, and concomitant medication use. The study was rated fair quality because there was no attempt to match patients on pain condition or severity of pain, or to adjust for these factors.

A good-quality case-control study compared 11,693 people with myocardial infarction from the UK General Practice Research Database to 44,897 controls with no myocardial infarction matched on age, sex, index date, and practice site.80 The most commonly prescribed opioids were codeine, propoxyphene, and dihydrocodeine. Although it did not specifically enroll patients with chronic pain, the study included an analysis stratified by duration of opioid use, based on the number of cumulative opioid prescriptions at the time of myocardial infarction. After adjustment for a number of factors, including smoking status, comorbidities, concomitant medications, type of pain, and recent or past opioid use, it found current opioid therapy use associated with increased risk of myocardial infarction versus nonuse (adjusted OR 1.28, 95 percent CI 1.19 to 1.37). Recent (within 31 to 365 days) use was also associated with increased risk (OR 1. 17, 95 percent CI 1.10 to 1.24). The risk was highest with 11 to 50 cumulative prescriptions (OR 1.38, 95 percent CI 1.28 to 1.49) but was statistically significant with 1-2, 3-10, or >50 cumulative prescriptions (OR range 1.09 to 1.25).

The SOE for the association between opioid use versus non-use and risk of myocardial infarction was rated Low.

We identified no study on the association between long-term opioid therapy for chronic pain versus no opioid therapy and risk of arrhythmia or sudden death.

#### Endocrinological Harms

The APS review included four studies on the effects of oral opioid use on endocrinological effects. One cross-sectional study of women with chronic pain (n=37, mean duration of opioid use 31 months) found no association between opioid use versus nonuse and growth hormone, corticotrophin, cortisol, thyroxine, thyrotropin, prolactin, estradiol, follicle stimulating hormone, luteinizing hormone, or testosterone levels, but did not meet inclusion criteria because it did not adjust for potential confounders.81 Three other cross-sectional studies found opioid use to be associated with decreased levels of gonadal hormone or dehydroepiandrosterone sulfate in men and women, but it was unclear in two of the studies whether patients had chronic pain, the duration of opioid use was not reported, none of the studies adjusted for potential confounders, and it was unclear how patients were selected, making it difficult to determine whether patients on opioids with signs of sexual or endocrinological dysfunction were preferentially enrolled.23, 24, 82

We identified one study published since the APS review on the association between opioid use versus nonuse and endocrinological harms (Appendix E5 and F2).11 In a cross-sectional analysis of men with back pain (n=11,327) in an integrated health care system, long-term opioid use (defined as ≥120 days or >90 days with 10 or more fills), compared with no opioid use, was associated with increased likelihood of use of medications for erectile dysfunction or testosterone replacement (adjusted OR 1.5, 95 percent CI 1.1 to 1.9), after adjustment for age, co-morbidities, hospitalizations, use of sedative-hypnotics, dose of opioids, type of opioid, depression, and smoking status. Median opioid dose in men on chronic opioids was 30 mg morphine equivalent dose (MED)/day (19 percent received ≥120 mg) and 42 percent received long-acting opioids. A limitation of this study is that the patient sample was a mix of acute, subacute, and chronic back pain, and the study could not control for duration of pain. In all studies, the cross-sectional design makes it impossible to determine whether endocrinological problems preceded opioid use or resulted from opioid use. One other cross-sectional study published since the prior APS review reported an association between long-term opioid use and laboratory markers of endocrinological dysfunction, but did not meet inclusion criteria because it did not perform adjustment for potential confounders.83

The SOE for the association between opioid use versus non-use and risk of endocrinological harms was rated Low.

#### Other Harms

We identified no studies on the association between long-term opioid therapy for chronic pain versus no opioid use and risk of falls, infections, cognitive harms, or psychological harms. These outcomes were not evaluated in the APS review.

## Key Question 2b How do harms vary depending on: (1) the specific type or cause of pain (e.g., neuropathic, musculoskeletal [including back pain], fibromyalgia, sickle cell disease, inflammatory pain, headache disorders); (2) patient demographics; (3) patient comorbidities (including past or current substance abuse disorder or at high risk for addiction); (4) the dose of opioids used?

### Key Points

- No study evaluated how harms associated with long-term opioid therapy vary depending on the specific type or cause of pain, patient demographics, or patient comorbidities (SOE: Insufficient).
- One fair-quality retrospective database study found higher doses of long-term opioid therapy associated with increased risk of opioid abuse or dependence than lower doses. Compared to no opioid prescription, the adjusted odds ratios were 15 (95 percent CI 10 to 21) for 1-36 mg MED/day, 29 (95 percent CI 20 to 41) for 36-120 mg MED/day, and 122 (95 percent CI 73 to 206) for ≥120 mg MED/day (SOE: Low).
- One fair-quality retrospective cohort study and one good-quality nested case-control study found an association between higher doses of long-term opioid therapy and risk of overdose. In the cohort study, versus 1 to 19 mg MED/day, the adjusted HR for an overdose event was 1.44 (95 percent CI 0.57 to 3.62) with 20 to 49 mg MED/day and increased with higher doses to 8.87 (95 percent CI 3.99 to 19.72) for ≥100 mg MED/day. The risk for serious overdose showed a similar pattern, with HRs of 1.19 (95 percent CI 0.4 to 3.6) for 20 to <50 mg MED/day, 3.11 (95 percent CI 1.01 to 9.51) for 50 to 99 mg/day, and 11.18 (95 percent CI 4.80 to 26.03) for ≥100 mg/day (all relative to 1-19 mg/day). In the case-control study, versus 1 to 19 mg MED/day, the adjusted OR for an opioid-related death was 1.32 (95 percent CI 0.94 to 1.84) for 20 to 49 mg MED/day and increased to 2.88 (95 percent CI 1.79 to 4.63) for ≥200 mg MED/day (SOE: Low).
- One fair-quality cohort study found that risk of fracture increased from an adjusted HR of 1.20 (95 percent CI 0.92 to 1.56) at 1 to <20 mg MED/day to 2.00 (95 percent CI 1.24 to 3.24) at ≥50 mg MED/day; the overall test for dose response did not reach statistical significance (P = 0.06) (SOE: Low).
- One fair-quality cohort study found that relative to a cumulative dose of 0 to <1350 mg MED over 90 days, the adjusted IRR for myocardial infarction for 1350 to <2700 mg was 1.21 (95 percent CI 1.02 to 1.45), for 2700 to <8100 mg was 1.42 (95 percent CI 1.21 to 1.67), for 8100 to <18,000 mg was 1.89 (95 percent CI 1.54 to 2.33), and for ≥18,000 mg was 1.73 (95 percent CI 1.32 to 2.26) (SOE: Low).
- One good-quality case-control study found no association between opioid dose and odds of road trauma injury among drivers and passengers.

Doses of opioids >20 mg MED/day were associated with increased odds of road trauma injury when the analysis was restricted to drivers. There was no dose-dependent association at doses higher than 20 mg MED/day. Relative to 1 to <20 mg MED/day, the adjusted odds of road trauma injury among drivers were 1.21 (1.02 to 1.42) for 20 to 49 (1.02 to 1.49) for >200 mg. (SOE: Low).

One fair-quality cross-sectional study of men found a daily opioid dose of ≥120 mg MED/day to be associated with increased odds of use of medications for erectile dysfunction or testosterone replacement versus 0 to <20 mg MED/day (adjusted OR 1.6, 95 percent CI 1.03 to 2.4). Odds were not increased at doses of 20 to <120 mg MED/day (SOE: Low).

### Detailed Synthesis

We identified no study on how harms associated with long-term opioid therapy vary depending on the specific type or cause of pain, patient demographics, or patient comorbidities, including those with a history of or at high risk for addiction.

The APS review identified no studies on the association between opioid dose and risk of harms in patients with chronic pain on long-term opioid therapy. We identified six studies published since the APS review on the association between opioid dose and risk of opioid-related deaths or overdose,61, 84 fractures,18 myocardial infarction,79 motor vehicle accidents,20 and endocrinological effects.11

#### Opioid Abuse, Addiction, and Related Outcomes

A previously described (see KQ 2a) fair-quality retrospective database study found a dose-dependent association between dose of long-term opioid therapy for chronic pain and risk of abuse or dependence.48 Based on ICD-9 diagnosis codes, rates of abuse or dependence were 0.7 percent with low-dose opioids (1-36 mg MED/day), 1.3 percent with medium-dose (36-120 mg MED/day), and 6.1 percent with high-dose (≥1 20 mg MED/day). Compared to no opioid prescription, the odds ratio for abuse or dependence after adjustment for age, sex, history of substance abuse and other comorbidities was 15 (95 percent CI 10 to 21) for low-dose, 29 (95 percent CI 20 to 41) for medium-dose, and 122 (95 percent CI 73 to 205) for high-dose opioids (Appendix E1) (SOE: Low).

#### Overdose

Two studies found an association between opioid dose and risk of overdose (Appendix E2, F1, and F3).61, 84 A previously described (see KQ 2a), fair-quality retrospective cohort study of patients (n=9,940) with recently diagnosed noncancer pain and prescribed opioid therapy followed patients for a mean duration of 42 months.61 Fifty-one patients experienced overdose events (148 per 100,000 person-years); 40 were serious overdose events (116 per 100,000 person-years) and 6 were fatal overdose events (17 per 100,000 person-years). After adjusting for smoking, depression, substance abuse, comorbid conditions, pain site, age, sex, recent sedative-hypnotic prescription, and recent initiation of opioid use, higher opioid dose was associated with increased risk of any overdose event. Relative to 1 to 19 mg MED/day, 20 to 49 mg/day was associated with a HR of 1.44 (0.57-3.62), 50-99 mg/day with a HR of 3.73 (1.47- 9.5), and ≥100 mg/day with a HR of 8.87 (3.99-19.72). The risk for serious overdose showed a similar pattern, with HRs of 1.19 (95 percent CI 0.4 to 3.6) for 20 to 49 mg MED/day, 3.11 (95 percent CI 1.01 to 9.51) for 50 to 99 mg/day, and 11.18 (95 percent CI 4.80 to 26.03) for ≥100 mg/day (all relative to 1-19 mg/day).

A good-quality, population-based, nested case-control study of Canadian patients eligible for publicly funded prescription drug coverage who had received an opioid for noncancer pain identified 498 cases of opioid-associated deaths.84 Cases were matched on age, sex, index year, the Charlson comorbidity index, and a disease risk index based on comorbidities to 1714 controls. Opioid-associated deaths were identified using coroner records and defined as deaths in which the coroner identified a combination of drugs including at least one opioid or in which forensic toxicology testing showed an opioid concentration sufficiently high to cause death.

Mean duration of opioid use was 5 years in cases and 4 years in controls. Long-acting opioids were dispensed at some point in the exposure period to 46 percent of cases and 30 percent of controls. After adjusting for previous drugs used, number of drugs, duration of opioid treatment, the number of physicians prescribing opioids, the number of pharmacies dispensing opioids, and prescribing of long-acting opioids, higher doses of opioids were associated with increased odds of opioid-associated mortality. Relative to 1 to 19 mg MED/day, the adjusted OR for opioid- associated mortality was 1.32 (95 percent CI 0.94 to 1.84) for 20 to 49 mg/day, 1.92 (95 percent CI 1.30 to 2.85) for 50 to 99 mg/day, 2.04 (95 percent CI 1.28 to 3.24) for 100 to 199 mg/day, and 2.88 (95 percent CI 1.79 to 4.63) for ≥200 mg/day (SOE: Low).

Three other observational studies also found an association between higher opioid doses and risk of opioid overdose-related deaths, but did not meet inclusion criteria because duration of opioid use was not reported,16, 85 emergency room visits for opioid-related overdose events were combined with emergency room visits for alcohol,86 or it did not evaluate patients with chronic pain prescribed long-term opioid therapy.85

#### Fractures

A previously described, fair-quality cohort study (see Key Question 2a) on the association between current use of opioids and risk of fractures in people aged 60 and older found that risk of fracture increased from an adjusted hazard ratio of 1.20 (95 percent CI 0.92 to 1.56) at 1 to <20 mg MED/day to 2.00 (95 percent CI 1.24 to 3.24) at ≥50 mg MED/day, although the overall test for dose response did not reach statistical significance (p = 0.06) (Appendix E3 and F2) (SOE: Low).18

#### Cardiovascular Events

A previously described fair-quality cohort study (see Key Question 2a) on the association between current use of opioids and risk of myocardial infarction in patients using long-term opioid therapy found a trend towards increased risk of myocardial infarction with higher cumulative opioid exposure (Appendix E4 and F1).79 Compared to a cumulative dose of 0 to <1350 mg MED over 90 days, the adjusted IRR for myocardial infarction for 1350 to <2700 mg was 1.21 (95 percent CI 1.02 to 1.45), for 2700 to <8100 mg was 1.42 (95 percent CI 1.21 to 1.67), for 8100 to <18,000 mg was 1.89 (95 percent CI 1.54 to 2.33), and for ≥18,000 mg was 1.73 (95 percent CI 1.32 to 2.26) (SOE: Low).

#### Motor Vehicle Accidents

We identified one good-quality case-control study (n=10,600) on the association of opioid dose with risk of motor vehicle accidents in Ontario, Canada among individuals eligible for provincial prescription drug coverage who received at least one opioid prescription (Appendix E6 and F3).20 It identified 5,300 cases who visited an emergency department with an injury related to road trauma. Cases were matched on sex, age, index year, and disease risk index to 5300 controls who did not visit the emergency department for road trauma. Although it did not specifically identify chronic pain patients on long-term opioid therapy, the average duration of opioid use was 7.1 years in cases and 6.8 years in controls. Individuals prescribed methadone were excluded because methadone is typically used to treat addiction in this area. Although there was no association between opioid dose and risk of road trauma in drivers or passengers at the time of the accident, doses of opioids >20 mg MED/day were associated with increased odds of road trauma when the analysis was restricted to drivers. There was no dose-dependent association at doses higher than 20 mg MED/day. Relative to 1 to <20 mg MED/day, the odds of road trauma among drivers after adjustment for age, alcoholism history, concomitant medication use, total number of drugs, and number of physician and emergency department visits was 1.21 (95 percent CI 1.02 to 1.42) for 20 to 49 mg, 1.29 (95 percent CI 1.06 to 1.57) for 50-99 mg, 1.42 (95 percent CI 1.15 to 1.76) for 100 to 199 mg, and 1.23 (95 percent CI 1.02 to 1.49) for ≥200 mg (SOE: Low).

#### Endocrinological Harms

One previously described fair-quality study cross-sectional analysis of men with back pain (n=11,327) found a daily opioid dose of ≥120 mg MED/day associated with increased risk of use of medications for erectile dysfunction or testosterone replacement versus 0 to <20 mg MED/day (OR 1.6, 95 percent CI 1.03 to 2.4), after adjustment for duration of opioid use, age, co- morbidities, hospitalizations, use of sedative-/hypnotics, type of opioid, depression, and smoking status (Appendix E5 and F2) (SOE: Low).11 There was no increased risk at doses of 20 to <120 mg MED/day.

## Key Question 3a In patients with chronic pain, what is the comparative effectiveness of different methods for initiating and titrating opioids for outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?

### Key Points

- Evidence from three trials on effects of titration with immediate-release versus sustained- release opioids reported inconsistent results on outcomes related to pain and are difficult to interpret due to additional differences between treatment arms in dosing protocols (titrated versus fixed dosing) and doses of opioids used (SOE: Insufficient).
- No trial was designed to assess risk of addiction, abuse, or misuse (SOE: Insufficient).

### Detailed Synthesis

The APS review included three fair-quality, open-label trials of sustained-release versus immediate release opioids for titrating patients to stable pain control (Appendix E7 and F4).87, 88 Two trials comparing controlled-release (CR) versus immediate-release (IR) oxycodone were reported in one publication.87 The first involved a sample of 48 patients with cancer pain and dose titration for a period up to 21 days.87 The second trial titrated 57 patients with low back pain for a period of up to 10 days.87 Most patients in both trials were converted to oxycodone from other opioids. Results of both trials showed no difference between CR and IR oxycodone with respect to the percentage of patients achieving stable pain control, the time to achieve stable pain control, and the degree of pain control achieved. Another trial found titrated doses of sustained- release morphine plus immediate-release oxycodone slightly superior to fixed-dose, immediate- release oxycodone for pain intensity, but no differences on measures of function, sleep, and psychological distress.88 Results of this trial are difficult to interpret because maximum doses of opioids varied in the two arms (up to 200 mg MED/day in titrated dose arm, versus up to 20 mg/day in the fixed-dose oxycodone arm), and average doses of opioids were not reported. None of the three trials was designed to assess outcomes related to risk of overdose, addiction, abuse, or misuse. Due to study limitations, inconsistent results, and differences between study arms other than use of sustained-release versus immediate-release opioids, the SOE was rated Insufficient.

We identified no study published since the APS review on the comparative effectiveness of different methods for initiating and titrating opioids.

## Key Question 3b In patients with chronic pain, what is the comparative effectiveness of short- versus long-acting opioids on outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?

### Key Points

- No study compared effectiveness of short- versus long-acting opioids on long-term outcomes in patients with chronic pain (SOE: Insufficient).

### Detailed Synthesis

The APS review included a systematic review89 of seven trials87, 88, 90-94 of short- versus long-acting opioid formulations, but none of the trials met inclusion criteria for the current review. Six trials87, 90-94 were 30 days or shorter in duration and the other88 was 16 weeks in duration. Five of the trials found no difference between sustained-release and immediate-release opioid formulations in pain control.87, 90, 91, 93, 94 Although two trials found regimens including sustained- release preparations more effective for pain control than regimens restricted to immediate-release preparations, results are difficult to interpret because the regimens were not given at therapeutically equivalent doses.88, 92 No trial was designed to evaluate risk of overdose, addiction, abuse, or misuse.

We identified no trials of short- versus long-acting opioids published since the APS review that met inclusion criteria.

## Key Question 3c In patients with chronic pain, what is the comparative effectiveness of different long-acting opioids on outcomes related to pain, function, and quality of life; and risk of overdose, addiction, abuse, or misuse?

### Key Points

- Three randomized, head-to-head trials of various long-acting opioids found no differences in long-term outcomes related to pain or function (SOE: Low).
- No trial was designed to assess risk of overdose, addiction, abuse, or misuse (SOE: Insufficient).
- One cohort study found sustained-release methadone to be associated with lower mortality risk (presumably related to accidental overdose) as compared to morphine in a propensity-adjusted analysis (SOE: Low).
- Another cohort study found some differences between long-acting opioids in rates of adverse outcomes related to abuse, but outcomes were nonspecific for opioid-related adverse events, precluding reliable conclusions (SOE: Insufficient).

### Detailed Synthesis

The APS review included one fair-quality, open-label randomized trial (n=680) of transdermal fentanyl versus sustained-release morphine in patients with chronic low back pain that evaluated outcomes through 13 months43 (Table 2 below; Appendix E8a, E8b, and F4). The study found no differences between these long-acting opioids in pain relief, pain intensity, use of supplemental analgesic medications, work loss, and quality of life. The study was not designed to assess overdose and addiction or related outcomes, and no cases of these outcomes were reported. The APS review also included a fair-quality retrospective cohort study based on Oregon Medicaid administrative data (n=5,684) that evaluated abuse and other related outcomes in patients with cancer or noncancer pain and at least one new 28-day prescription of methadone, sustained-release oxycodone, sustained-release morphine, or transdermal fentanyl over a 4-year timeframe.95 Adverse events were based on clinical encounters and ICD-9 codes and defined as emergency department (ED) visits or hospitalization for opioid-related events, all-cause ED visits or hospitalizations, opioid poisoning, overdose symptoms, and death. After adjusting for opioid dose, co-morbidities, concomitant medications, and other potential confounders, sustained-release oxycodone was associated with lower risk than sustained-release morphine of an ED encounter or hospitalization involving an opioid-related adverse event (HR 0.45, 95 percent CI 0.26 to 0.77) or death (HR 0.71, 95 percent CI 0.54 to 0.94). Among patients with noncancer pain, compared with sustained-release morphine, fentanyl was associated with higher risk of ED encounters (HR 1.27, 95 percent CI 1.02 to 1.59) and methadone was associated with greater risk of overdose symptoms (HR 1.57, 95 percent CI 1.03 to 2.40). There were no significant differences between methadone and long-acting morphine in risk of death (adjusted HR 0.71, 95 percent CI 0.46 to 1.08) or overdose symptoms. Some limitations of this study include large, statistically significant differences in baseline characteristics between patients prescribed different long-acting opioids and analysis of outcomes not specific for opioid-related adverse events. For example, overdose symptoms were defined as alteration of consciousness, malaise, fatigue, lethargy, or respiratory failure.

Table 2 Head-to-head trials and observational studies of different long-acting opioids

Author Year Study Design Duration | Setting/Data Source Country | Interventions, N | Results | Quality
Allan, 2005^43^ Randomized trial 13 months | Multicenter (number of sites not clear) Europe | A: Transdermal fentanyl (titrated from 25 mcg/hr) (Mean dose 57 mcg/hr) (N=338) B: Sustained-release morphine (titrated from 30 mg q 12 hrs) (Mean dose: 140 mg) (N=342) | A vs. B Pain score (mean, 0-100 VAS) at 56 weeks (N=608): 56.0 vs. 55.8 Severe pain at rest (per protocol analyses, N=248 and 162): 22/248 (9%) vs. 20/162 (12%), p=0.030 (no significant differences in ITT analysis, but data not provided) Severe pain on movement (per protocol): 70/248 (28%) vs. 43/162 (27%), p=0.611 Severe pain during the day (per protocol): 48/248 (19%) vs. 40/162 (25%), p=0.385 Severe pain at night (per protocol): 25/248 (10%) vs. 26/162 (16%), p=0.003 (no significant differences in ITT analysis, but data not provided) Rescue strong opioids use: 154/296 (52%) vs. 154/291 (53%) Quality of life (SF-36): No differences between interventions Loss of working days: No differences between interventions Withdrawal due to lack of efficacy: 18/335(5%) vs. 15/342 (4%) | Fair
Hartung, 2007^95^ Retrospective cohort study Duration not applicable | U.S. Medicaid claims | A. Transdermal fentanyl (n=1,546) B. Methadone (n=974) C. ER oxycodone (n=1,866) D. ER morphine (n=1,298) | A vs. B vs. C (reference: D) Mortality: adjusted HR 0.71 (95% CI 0.46 to 1.08) vs. HR 0.71 (95% CI 0.54 to 0.94) vs. 0.80 (95% CI 0.63 to 1.02) ED encounter or hospitalization involving an opioid-related adverse event (HR 0.45, 95% CI 0.26 to 0.77) Among patients with noncancer pain: Fentanyl associated with higher risk of ED encounters than sustained-releasemorphine (HR 1.27, 95% CI 1.02 to 1.59) Methadone associated with greater risk of overdose symptoms than sustained-release morphine (HR 1.57, 95% CI 1.03 to 2.40) No significant differences between methadone and long-acting morphine in risk of death (adjusted HR 0.71, 95% CI 0.46 to 1.08) | Fair
Krebs, 2011^98^ Retrospective cohort study Duration not applicable | U.S. VA | A: Methadone (n=28,554) B: Long-acting morphine sulfate (MS) (n=79,938) | All-cause mortality: Unadjusted: 3,347 (3.4%) patients died; highest mortality within 1st 30 days (1.2% in methadone and 3.7% in MS); raw death rates from MS higher than methadone for all 30-day intervals; Death rate: Quintile #1 (0.042 vs 0.133); Quintile #2 (0.034 vs 0.078); Quintile #3 (0.025 vs 0.053); Quintile #4 (0.022 vs 0.034); Quintile #5 (0.017 vs 0.020); Propensity adjusted mortality (HR): Overall risk of mortality lower with methadone than morphine (adjusted HR 0.56, 95% CI 0.51 to 0.62) Quintile #1: 0.36 (95% CI: 0.26, 0.49); Quintile #2: 0.46 (0.37, 0.56); Quintile #3: 0.50 (0.41, 0.61); Quintile #4: 0.66 (0.54, 0.81); Quintile #5: 0.92 (0.74, 1.16); Results robust in validation dataset | Fair
Mitra, 2013^96^ Randomized trial 12 months | Townsville, Australia (1 site) | A: Transdermal buprenorphine (TDB) initial dose=-5 mcg/h (n=22) B: Transdermal fentanyl (TDF) initial dose=12.5 mcg/h (n=24) Both titrated to optimal doses over 4 weeks; increased doses beyond that given as clinically indicated | Sleep quality: No significant difference between groups (data not provided) Pain VAS: 3-point (scale 1-10) reduction in pain in 11% in each treatment group (data not provided) DASS21: TDB had relatively better score at 12 mos (data not provided) PDI: Appears similar (data not provided) | Poor
Wild, 2010^97^ Randomized trial 12 months | 53 sites in North America; 36 sites in Europe | A. Tapentadol ER 100-250 mg BID (adjustable) (n=894) B. Oxycodone CR 20-50 mg BID (adjustable) (n=223) | Mean (SE) pain intensity score: decreased from 7.6 (0.05) and 7.6 (0.11) at baseline to 4.4 (0.09) and 4.5 (0.17) Global assessment, very much improved or much improved: 48.1% (394/819) vs 41.2% (73/177) Concomitant nonopioid analgesics (NSAIDS, ASA, acetaminophen): 19.9% (178/894) vs. 17% (38/223) | Fair

Abbreviations: ASA=aspirin, BID=twice daily, CI=confidence interval, CR=controlled release, DASS21=Depression, Anxiety, and Stress Scale-21 Items, ER=extended release, HR=hazard ratio, ITT=intent to treat, MS=long-acting morphine sulfate, NSAID=nonsteroidal anti-inflammatory drug, PDI=Physical Disability Index, q=every, SE=standard error, TDB= transdermal buprenorphine, TDF= transdermal fentanyl, US=United States, VA=Veterans Affairs, VAS=Visual Analogue Scale.

We identified two randomized trials96, 97 and one retrospective cohort study98 published since the APS review that compared different long-acting opioids in patients receiving long­term opioid therapy. One large (n=1,117) fair-quality trial of patients with chronic low back pain or osteoarthritis pain found no difference between sustained-release tapentadol and sustained- release oxycodone in pain intensity through 1 year.97 Methodological limitations included open- label design and high attrition. A smaller (n=46), poor-quality trial of patients with various types of chronic noncancer pain (61 percent low back pain) found no clear differences between transdermal buprenorphine versus transdermal fentanyl in pain intensity, pain relief, quality of life, function, or psychological symptoms through 1 year.96 It was rated poor-quality due to high attrition and open-label design. In addition, statistical analyses comparing results between groups were not reported for most outcomes and the study was not designed to measure efficacy. No deaths were reported in either study, and the studies were not designed to assess risk of addiction, abuse, or misuse. In both trials, opioid doses were titrated to effect.

A fair-quality retrospective cohort study based on national VA system pharmacy data compared all-cause mortality among chronic pain patients prescribed methadone (n=28,554) or long-acting morphine (n=79,938).98 The study excluded patients prescribed methadone for opioid dependence or in palliative care settings. The mean daily doses of methadone and long acting morphine were 25.4 mg and 67.5 mg, respectively. Compared to the morphine cohort, the methadone group was younger and had fewer comorbid medical conditions, but higher rates of psychiatric conditions, substance use, and back pain. To help control for these and other differences, the study analyzed patients based on their propensity for being prescribed methadone. The baseline characteristics in each propensity quintile were very similar across the two groups. In both groups, all-cause mortality was highest in propensity quintile 1 (patients with the least propensity to receive methadone and most medically ill) and least in quintile 5 (highest propensity to receive methadone). In the propensity-stratified analysis, overall risk of mortality was lower with methadone than with morphine (adjusted HR 0.56, 95 percent CI 0.51 to 0.62).

For propensity quintile 1, the adjusted HR was 0.36 (95 percent CI 0.26 to 0.49); similar trends were observed for quintiles 2 to 4. For quintile 5, there was no difference between methadone and morphine in risk of all-cause mortality (adjusted HR 0.92, 95 percent CI 0.74 to 1.2). The main limitation of this study is the possibility of residual confounding by indication. Although the study stratified patients based on their propensity for being prescribed methadone and performed adjustment on potential confounders, unmeasured confounders could still have been present. The likely effects of residual confounding on estimates is difficult to predict, because people prescribed methadone had features associated both with decreased risk of mortality (younger age and fewer co-morbid medical conditions) as well as with increased risk (more psychiatric conditions and substance abuse).

The SOE was rated Low for no difference between different long-acting opioids in pain or function, Low for mortality risk associated with methadone versus morphine, and Insufficient for abuse and related outcomes.

## Key Question 3d In patients with chronic pain, what is the comparative effectiveness of short- plus long-acting opioids versus long-acting opioids alone on outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?

The APS review identified no trial of short- plus long-acting opioids versus long-acting opioids alone. We also identified no study published since the APS review that addressed this question (SOE: Insufficient).

## Key Question 3e In patients with chronic pain, what is the comparative effectiveness of scheduled, continuous versus as-needed dosing of opioids on outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?

### Key Points

- No study compared long-term opioid therapy using scheduled, continuous dosing versus as-needed dosing (SOE: Insufficient).

### Detailed Synthesis

The 2009 APS review included one trial of scheduled, around-the-clock dosing of codeine versus as-needed dosing, but it did not meet inclusion criteria for the current review because duration of followup was five days.92 In addition, results of this trial were difficult to interpret because the interventions varied on factors other than whether the opioid was dosed around-the- clock, including use of sustained-release versus immediate-release codeine formulations and different doses (200 versus 71 mg/day of codeine).

We identified no study published since the APS review on long-term opioid therapy using scheduled, continuous dosing versus as-needed dosing (SOE: Insufficient).

## Key Question 3f In patients on long-term opioid therapy, what is the comparative effectiveness of dose escalation versus dose maintenance or use of dose thresholds on outcomes related to pain, function, and quality of life?

### Key Points

- One fair-quality randomized trial of more liberal dose escalation versus maintenance of current doses found no difference in outcomes related to pain or function, or risk of withdrawal due to opioid misuse, but achieved limited separation between groups in opioid doses (52 versus 40 mg MED/day at the end of the trial) (SOE: Low).

### Detailed Synthesis

The APS review did not address the comparative effectiveness of dose escalation versus dose maintenance or use of dose thresholds. We identified one relevant fair-quality randomized trial (n=140) published since the APS review (Appendix E9 and F4).99 It compared more liberal dose escalation (doses increased for inadequate pain relief using preset dosing guidelines) versus maintenance of current doses (doses only increased if medically necessary due to clear dosage tolerance or acute injury). The subjects were VA patients with primarily musculoskeletal chronic pain99 (defined as >6 months duration). Over 90 percent of enrollees were male and initial opioid doses were about 30 mg morphine equivalents/day. Both short- and long-acting opioids were prescribed, with long-acting opioids used more at higher doses. Average pain at baseline was about 7 on a 0 to 10 scale, and mean Oswestry Disability Index (ODI) score was about 48 (indicating moderate functional disability). The trial was fair-quality, primarily due to high attrition. Although doses at the end of the 12-month trial were higher in the dose escalation group, an important limitation of this trial is that the difference in opioid doses prescribed at the end of the trial was relatively small (mean 52 versus 40 mg morphine equivalents/day).

The trial found no difference between groups at 12 months in mean Visual Analogue Scale (VAS) pain ratings (5.6 for escalating dose versus 6.2 for stable dose, p=0.11), proportion with ≥1.5 point improvement in VAS pain rating (28 percent versus 20 percent, RR 1.4, 95 percent CI 1.76 to 2.5), mean ODI scores (46 versus 45, p=0.85), proportion with ≥10 point improvement in ODI score (29 percent versus 23 percent, RR 1.0, 95 percent CI 0.61 to 1.8), or use of various nonopioid medications or physical therapy. There was also no significant difference in all-cause withdrawals (49 percent versus 56 percent, RR 0.88, 95 percent CI 0.64 to 1.2). Withdrawal due to opioid misuse was frequent in both groups, with no difference between groups (24 percent versus 30 percent, RR 0.79, 95 percent 0.46 to 1.4) (SOE: Low).

## Key Question 3g In patients on long-term opioid therapy, what is the comparative effectiveness of opioid rotation versus maintenance of current opioid therapy on outcomes related to pain, function, and quality of life; and doses of opioids used?

### Key Points

- No study compared opioid rotation versus maintenance of long-term opioid therapy (SOE: Insufficient).

### Detailed Synthesis

The APS review identified no randomized trials or controlled observational studies on opioid rotation versus maintenance of current therapy. We identified no studies published since the APS review that addressed this Key Question (SOE: Insufficient).

## Key Question 3h In patients on long-term opioid therapy, what is the comparative effectiveness of different strategies for treating acute exacerbations of chronic pain on outcomes related to pain, function, and quality of life?

### Key Points

- Two good-quality randomized trials found buccal fentanyl more effective than placebo for treating acute exacerbations of pain and three randomized trials found buccal fentanyl or intranasal fentanyl more effective than oral opioids for treating acute exacerbations of pain in patients on long-term opioid therapy, based on outcomes measured up to 2 hours after dosing. (SOE: Moderate).
- No study evaluated long-term benefits or harms (SOE: Insufficient).

### Detailed Synthesis

The APS review included two placebo-controlled, randomized trials (n=77 and 79) of buccal fentanyl for acute exacerbations of pain in people prescribed opioid therapy for chronic pain (Table 3 below, Appendix E10 and F4).100, 101 Both found buccal fentanyl to be more effective than placebo at relieving acute pain exacerbations based on outcomes measured up to 2 hours after dosing, for up to nine episodes over a 3-week period. Neither trial was designed to evaluate benefits or harms associated with longer-term use of buccal fentanyl, including outcomes related to abuse and associated outcomes. Use of a run-in period in both trials could limit generalizability of findings, as about one-quarter of patients were excluded during an open-label run-in period due to lack of efficacy or adverse events.

Table 3 Trials of different strategies for treating acute exacerbations of chronic pain in patients on long-term opioid therapy

Author, Year Study Design Duration | Sample | Interventions, N | Results | Quality
Ashburn, 2011^102^ Randomized trial (crossover) Duration: up to 42 days total | n=183 Patients aged 18 to 80 years with >3 months of chronic pain receiving >60 mg/day MED, with 1-4 episodes of breakthrough pain per day Mean age: 48.8 years Female sex: 62% Race: 92% White, 5% Black, 3% other Pain intensity in 24 hours prior to enrollment: 5.1 Indication (most common): 57% back pain, 11% osteoarthritis, 8% neck pain, 9% fibromyalgia, 4% traumatic injury, 4% complex regional pain syndrome | A. Fentanyl buccal tablet (n=183) B. Oxycodone (n=183) | A vs. B Pain intensity difference (from before drug administration; 0-10 scale) at 15 minutes: 0.82 vs. 0.60 (p<0.0001) Pain relief (0-5 scale) at 15 minutes: 0.69 vs. 0.53 (p<0.05) Meaningful pain relief within 15 minutes: 16% vs. 12% of episodes (p<0.05) | Good
Davies, 2011^103^ Randomized trial (crossover) 3 to 21 days | n=84 Patients with histologically confirmed cancer, receiving a fixed-schedule opioid regimen at a total daily dose equivalent >60 mg MED, with 1 to 4 episodes of breakthrough pain per day Mean age: 55.9 years Female sex: NR Race: NR | A. Fentanyl pectin nasal spray (n=106 for safety and n=84 for efficacy) B. Immediate-release morphine sulfate (n=106 for safety and n=84 for efficacy) | A vs. B ≥2-point reduction in pain intensity at 10 minutes: 52.4% vs. 45.4% (p<0.05) ≥2 pain relief at 15 minutes: 60.2% vs. 53.4% (p<0.05) Total pain relief ≥33% at 15 minutes: 52.3% vs. 43.5% (p<0.01) | Fair
Portenoy, 2007^100^ Randomized trial 3 weeks | n=77 Patients aged 18 to 80 years with chronic low back pain Mean age: 47 years Female gender: 55% Nonwhite race: 12% Baseline pain intensity: 5.1 (10 point scale) Primary etiology of low back pain degenerative disc disease: 68% | A. Buccal fentanyl 100 to 800 mcg for an episode of breakthrough pain B. Placebo (n=77) Dose of buccal fentanyl: 800 mcg 56%; 600 mcg 24%; 400 mcg 15%; 200 mcg 5% | A vs. B Sum of the pain intensity differences from 5 through 60 minutes: 8.3 vs. 3.6 Proportion of breakthrough pain episodes with “meaningful” pain reduction: 70% (289/413) vs. 30% (63/207) (p<0.0001) Proportion of breakthrough pain episodes with ≥33% reduction in pain intensity after 30 minutes: 42% (172/413) vs. 18% (18/207) (p<0.0001) Proportion of breakthrough pain episodes with ≥50% reduction in pain intensity after 30 minutes: 30% (122/413) vs. 13% (27/207) (p<0.0001) Proportion of breakthrough pain episodes with ≥33% reduction in pain intensity after 120 minutes: 65% (269/413) vs. 28% (57/207) (p<0.0001) Proportion of breakthrough pain episodes with ≥50% reduction in pain intensity after 120 minutes: 48% (198/413) vs. 16% (33/207) (p<0.0001) | Good
Simpson, 2007^101^ Randomized trial (crossover) 3 weeks | n=79 18 to 80 years old, >3 months history of chronic neuropathic pain associated with diabetic peripheral neuropathy, postherpetic neuralgia, traumatic injury, or complex regional pain syndrome, on chronic opioids (at least 60 mg/day or morphine or equivalent), pain intensity <7 on a 0 to 10 scale, 1 to 4 daily episodes of breakthrough pain | A. Buccal fentanyl 100 to 800 mcg for an episode of breakthrough pain B. Placebo (n=79) Dose of buccal fentanyl: 800 mcg 54%; 600 mcg 19%; 400 mcg 18%; 200 mcg 5%, 100 mcg 5% | A vs. B Sum of the pain intensity differences from 5 through 60 minutes: 9.63 vs. 5.73 (p<0.001) Proportion of breakthrough pain episodes with 'meaningful' pain reduction: 69% vs. 36% (p<0.0001) Proportion of breakthrough pain episodes with ≥50% reduction in pain intensity after 15 minutes: 12% vs. 5% (p≤0.0001), p<0.0001 for each subsequent time point from 30 to 120 minutes Use of supplemental medication: 14% (59/432) vs. 36% (77/213) (OR 0.28, 95% CI 0.18 to 0.42) | Good
Webster,2013^104^ Randomized trial (crossover) Up to 42 days | N=274 Mean age: 50.8 years Female sex: 58% Race: 91 % white, 7% black, 2% other Pain intensity in 24 hours prior to enrollment: 5.1 | A. Fentanyl buccal tablet (n=137) B. Oxycodone (n=137) | A vs. B Pain intensity difference (from before drug) at 15 minutes: 0.88 vs. 0.76 (0-10 scale) (p<0.001) Pain relief at 15 minutes: 38% vs. 34% (p<0.05) Meaningful pain relief within 15 minutes: 17% vs. 16% (p=NS) Meaningful pain relief within 30 minutes: 46% vs. 38% (p<0.01) | Good

Abbreviations: CI=confidence interval, MED=morphine equivalent dose, NR=not reported, NS=not significant, OR=odds ratio.

We identified three subsequent head-to-head trials of buccal or intranasal fentanyl versus oral opioids for acute exacerbations of chronic pain.102-104 As in the prior trials, all were funded by the manufacturer of buccal or intranasal fentanyl or conducted by researchers affiliated with the manufacturer. All used a double-blind, double-dummy crossover design and enrolled patients prescribed ≥60 mg MED/day and with one to four episodes of pain exacerbations per day. Like the prior trials, they focused on immediate outcomes following administration and used a run-in period. Two good-quality trials (n=183 and 137) found fentanyl buccal tablets to be more effective than oxycodone in reducing pain intensity (pain reduction 0.82 versus 0.60 and 0.88 versus 0.76 on a 0-10 scale; both p<0.001) and meaningful pain relief (undefined) (16 percent versus 12 percent at 15 minutes, p<0.05 and 46 percent versus 38 percent at 30 minutes, p<0.01).102, 104 The pain condition in most patients in both trials was back or neck pain, osteoarthritis, fibromyalgia, traumatic injury, or complex regional pain syndrome. A fair-quality trial (n=84) of cancer patients found fentanyl pectin nasal spray more effective than immediate- release morphine sulfate at reducing pain intensity by >33 percent at 15 minutes (52 percent versus 44 percent of episodes; p<0.01).103 It was unclear how many of the patients in the study were at end of life.

The SOE for the effectiveness of buccal or nasal fentanyl for immediate pain relief was rated Moderate.

## Key Question 3i In patients on long-term opioid therapy, what are the effects of decreasing opioid doses or of tapering off opioids versus continuation of opioids on outcomes related to pain, function, quality of life, and withdrawal?

### Key Points

- One small (n=10), poor-quality crossover trial found abrupt cessation of morphine to be associated with increased pain and decreased function compared to continuation of morphine (SOE: Insufficient).

### Detailed Synthesis

The APS review included one small (n=10), poor-quality crossover trial that found abrupt cessation of morphine to be associated with increased pain and decreased function compared to continuation of morphine (Appendix E11 and F4).105 Three patients (30 percent) reported opioid withdrawal symptoms following abrupt cessation of morphine, though there were no differences in physiologic parameters (vital signs and pupil size). Average dose of morphine prior to entry into was 42 mg/day (range 30 to 120 mg/day). Results of this trial may not apply to the general population of patients with chronic pain, as patients who did not have pain adequately controlled by immobilization and alternative medications were excluded from study entry. We identified no study published since the APS review addressing this question.

## Key Question 3j In patients on long-term opioid therapy, what is the comparative effectiveness of different tapering protocols and strategies on measures related to pain, function, quality of life, withdrawal symptoms, and likelihood of opioid cessation?

### Key Points

- Two poor-quality, nonrandomized prospective trials found no clear differences between different methods for opioid discontinuation or tapering (inpatient, patient controlled versus fixed reduction schedule or detoxification plus counseling versus detoxification plus maintenance) in likelihood of opioid abstinence after 3 to 6 months (SOE: Insufficient).

### Detailed Synthesis

The APS review included two poor-quality, nonrandomized prospective trials that reported similar rates of opioid abstinence after 3 to 6 months in patients allocated to different methods for opioid discontinuation or tapering (Appendix E12 and F4).106, 107 In one study (n=108), patients either chose inpatient, patient-controlled reduction of opioids or a fixed reduction schedule.106 Mean opioid dose on study entry was 36 mg MED/day; duration of opioid therapy was not reported. In the second study, patients (n=42) received detoxification plus counseling or detoxification with maintenance therapy if detoxification was unsuccessful.107 Mean duration of opioid use was 7.2 years in the detoxification plus counseling group and 9.2 years in the detoxification plus maintenance group; opioid doses ranged widely (e.g., codeine daily doses ranged from 240 to 2400 mg/day). Neither study evaluated effects of different methods for discontinuing opioids on pain, function, quality of life, or withdrawal symptoms.

We identified no study published since the APS review on the comparative effectiveness of different tapering protocols and strategies in chronic pain patients on long-term opioid therapy.

## Key Question 4a In patients with chronic pain being considered for long-term opioid therapy, what is the accuracy of instruments for predicting risk of opioid overdose, addiction, abuse, or misuse?

### Key Points

- Three studies (one fair-quality, two poor-quality) evaluated the Opioid Risk Tool (ORT); using a cutoff of ≥4. Estimates of diagnostic accuracy were inconsistent, precluding reliable conclusions. Sensitivities ranged from 0.20 to 0.99; specificities for the two in which this could be calculated were 0.88 and 0.16 (SOE: Insufficient).
- Two studies evaluated the Screening and Opioid Assessment for Patients with Pain (SOAPP) Version 1 instrument. In one fair-quality study, based on a cutoff score of ≥8, sensitivity was 0.68 and specificity was 0.38, for a PLR of 1.11 and NLR of 0.83 for predicting aberrant urine drug test. In one poor-quality study, sensitivity for predicting opioid discontinuation due to aberrant drug-related behavior was 0.73 based on a cutoff score of >6 and other diagnostic accuracy indicators could not be determined. (SOE: Low).
- One poor-quality study evaluated the Diagnosis, Intractability, Risk, and Efficacy Inventory (DIRE), but specificity and other diagnostic accuracy indicators could not be determined as patients who were not discontinued from opioids were not included in this study. (SOE: Insufficient)
- One poor-quality study evaluated the Pain Medication Questionnaire (PMQ), and for a cutoff of scores ≥30, sensitivity was low (0.34), specificity was 0.77, and AUROC was 0.57 for predicting opioid discontinuation due to aberrant drug-related behaviors. (SOE: Insufficient)
- One poor-quality study evaluated the Screening and Opioid Assessment for Patients with Pain-Revised (SOAPP-R). For a cutoff of ≥18, sensitivity was 0.39 and specificity was 0.69 and AUROC was 0.54 for predicting opioid discontinuation and discharge due to aberrant drug-related behavior. (SOE: Insufficient)

### Detailed Synthesis

The APS review108 included two fair-quality prospective studies of instruments to predict risk of opioid abuse or misuse completed by patients before initiation of opioid therapy (Table 4 below; Appendix E13 and F5).109, 110 One study109 evaluated the 14-item, patient self- administered Screening and Opioid Assessment for Patients with Pain (SOAPP) Version 1 instrument111 and the other110 evaluated the 10-item, self-administered Opioid Risk Tool (ORT). The SOAPP is scored on a scale of 0 to 56, while ORT scores can range from 0 to 25. For both instruments, higher scores indicate greater risk of opioid misuse and patients with scores ≥8 are considered high-risk for abuse. Both studies were performed with samples of patients in pain clinics. Methodological shortcomings of both studies included unclear blinding of outcomes assessors to findings of the screening instrument, use of definitions for aberrant drug-related behaviors that were not well standardized or defined, and failure to distinguish less serious from more serious behaviors. Although the APS review included two other studies used to develop the SOAPP Version 1^111^ and the Revised SOAPP,112 both were conducted using samples of patients already on long-term opioid therapy and did not meet inclusion criteria for the current review. In these studies, sensitivities (0.80 and 0.91) and specificities (0.68 and 0.69) were higher than those reported in the study of the SOAPP Version 1^109^ conducted in patients evaluated prior to initiation of treatment.

Table 4 Studies of risk assessment instruments

Author Year | Population, N | Risk Assessment | Method of Administratio | Reference Standard
Akbik, 2006^109^ | n=155 Mean age 43 years (SD 9.6) 33% female 86% White, other races not reported Pain: 39% back | SOAPP (scale 0-56; high risk ≥8) | Self-report | Positive urine drug test
Jones, 2012^113^ (Study 2) | n=263 Mean age 48 years (SD 13) 56% female 96% White, other races not reported Pain: 45% low back pain, 21 % arthritis or fibromyalgia), 14% joint pain, 10% pelvic or abdominal pain, 7% neck or upper back pain | ORT (scale 0-25; high risk ≥8) PMQ (scale 0-104; high risk ≥30) SOAPP-R (scale 0- 24; high risk ≥18 Clinician assessment | Self-report (SOAPP-R, ORT, PMQ); clinician interview | Opioid discontinuation due to abuse
Moore, 2009^114^ | n=48 Mean age 44 years (SD 11) 60% female Race not reported Pain not reported | SOAPP (scale 0-56; high risk ≥8) DIRE (scale 7-21; high-risk ≤13) ORT (scale 0-26; high risk ≥8) Clinician assessment | Self-report (SOAPP, DIRE, ORT); clinician interview | Opioid discontinuation due to abuse^a^
Webster, 2005^110^ | n=185 Mean age 44 years (SD 13) 58% female Race not reported Pain: 45% back; 18% head; 16% neuropathic; 16% musculoskeletal; 5%visceral | ORT (scale 0-25; high risk ≥8) | Self-report | Documentation in medical record of aberrant behavior during followup

Abbreviations: DIRE= Diagnosis Intractability Risk and Efficacy Inventory, ORT= Opioid Risk Tool, PMQ=Pain Medication Questionnaire, SD=standard deviation, SOAPP= Screening and Opioid Assessment for Patients with Pain, SOAPP-R= Screening and Opioid Assessment for Patients with Pain-Revised.

The study of the SOAPP Version 1 instrument111 reported a sensitivity of 0.68 (95 percent CI 0.52 to 0.81) and specificity of 0.38 (95 percent CI 0.29 to 0.49) based on a cutoff score of ≥8, for a PLR of 1.11 (95 percent CI 0.86 to 1.43) and NLR of 0.83 (95 percent CI 0.50 to 1.36) (Table 5 below).109 Results were difficult to interpret because the only outcome reported was aberrant urine drug test, urine drug screens were not obtained in most patients, and duration of followup was unclear.

Table 5 Predictive value of risk assessment instruments

Scale | Studies | Sensitivity | Specificity | Positive Likelihood Ratio | Negative Likelihood Ratio | AUROC
DIRE | Moore, 2009^114^ | Score <14: 0.17 | Not calculable^a^ | Not calculable^a^ | Not calculable^a^ | Not calculable^a^
ORT | Jones, 2012^113^ | Score >4: 0.20 (95% CI 0.15 to 0.27) | Score >4: 0.88 (95% CI 0.82 to 0.93) | Score >4: 1.65 (95% CI 0.78 to 3.51) | Score >4: 0.91 (95% CI 0.78 to 1.06) | 0.54
ORT | Moore, 2009^114^ | Score ≥4: 0.45 | Not calculable^a^ | Not calculable^a^ | Not calculable^a^ | Not calculable^a^
ORT | Webster, 2005^110^ | Score ≥4: 0.99 (95% CI 0.92 to 0.99) | Score ≥4: 0.16 (95% CI 0.10 to 0.24) | Score ≥4: 0.99 (95% CI 0.92 to 0.999) Score 1-3: 0.08 (95% CI 0.01 to 0.62) Score 4-7: 0.57 (95% CI 0.44 to 0.74) Score ≥8: 14.34 (95% CI 5.35 to 38) | Score ≥4: 0.16 (95% CI 0.10 to 0.24) | Not reported
PMQ | Jones, 2012^113^ | Score ≥30: 0.34 (95% CI 0.20 to 0.51) | Score ≥30: 0.77 (95% CI 0.69 to 0.80) | Score ≥30: 1.46 (95% CI 0.87 to 2.45) | Score ≥30: 0.86 (95% CI 0.68 to 1.08) | 0.57
SOAPP- R | Jones, 2012^113^ | Score ≥18: 0.39 (95% CI 0.26 to 0.54) | Score ≥18: 0.69 (95% CI 0.63 to 0.75) | Score ≥18: 1.27 (95% CI 0.86 to 1.90) | Score ≥18: 0.88 (95% CI 0.70 to 1.10) | 0.54
SOAPP | Moore, 2009^114^ | Score >6: 0.73 | Not calculable^a^ | Not calculable^a^ | Not calculable^a^ | Not calculable
SOAPP | Akbik, 2006^109^ | Score ≥8: 0.68 (95% CI 0.52 to 0.81) | Score ≥8: 0.38 (95% CI 0.29 to 0.49) | Score ≥8: 1.11 (95% CI 0.86 to 1.43) | Score ≥8: 0.83 (95% CI 0.50 to 1.36) | Not reported

a Retrospective study; only patients who had discontinued opioids due to aberrant drug-related behavior were included. Abbreviations: CI=confidence interval, DIRE= Diagnosis Intractability Risk and Efficacy Inventory, ORT= Opioid Risk Tool, PMQ=Pain Medication Questionnaire, SOAPP= Screening and Opioid Assessment for Patients with Pain, SOAPP-R=Screening and Opioid Assessment for Patients with Pain-Revised.

In the study110 of the ORT, items in the ORT were chosen and weighted before evaluation of diagnostic test characteristics, and cut-off scores for different risk categories appeared to be selected on an a priori basis. Aberrant drug-related behaviors as documented in medical records over 12 months of follow-up were identified in 6 percent (1/18) of patients categorized as low risk (score 0 to 3), compared with 28 percent (35/123) of patients categorized as moderate risk (score 4 to 7) and 91 percent (41/44) of those categorized as high risk (score ≥8), for PLRs of 0.08 (95 percent CI 0.01 to 0.62) for a low-risk score, 0.57 (95 percent CI 0.44 to 0.74) for a moderate-risk score, and 14.34 (95 percent 5.35 to 38) for a high-risk score (Table 5 below).110

We identified two subsequent poor-quality retrospective studies that compared the ability of different risk assessment instruments to predict subsequent opioid abuse or misuse.113, 114 One study compared the ORT, the Revised (24-item) SOAPP (SOAPP-R), the Pain Medication Questionnaire (PMQ), and a semi-structured clinical interview.113 SOAPP-R scores range from 0 to 24 (scores ≥18 indicate high risk) and PMQ scores range from 0 to 104 (scores ≥30 indicate high risk.) The other compared the SOAPP Version 1, the ORT, the Diagnosis, Intractability, Risk, and Efficacy Inventory (DIRE) instrument, and a semi-structured clinical interview.114 DIRE scores range from 7 to 21, and unlike the other risk assessment instruments, lower scores (≤13) indicate high-risk for abuse. Both studies appeared to be conducted in the same pain clinic during different time periods. Methodological shortcomings in both studies included exclusion of patients who were not evaluated with all of the risk assessment instruments (in one study, nearly 300 of 347 patients were excluded for this reason,113 and in the other the proportion excluded was not reported114) and use of a case-control design. In both studies, cases were based on opioid discontinuations due to abuse, without further specification. One study also evaluated aberrant behaviors, but this outcome was not clearly defined.114

One poor-quality study found the ORT (cutoff >4), PMQ (cutoff ≥30) and SOAPP-R (cutoff ≥1 8) associated with sensitivities of 0.20, 0.34, and 0.39, respectively, and specificities of 0.88, 1.77 and 0.69, resulting in weak positive likelihood ratios (PLR; range 1.27 to 1.65) and negative likelihood ratios (NLR; range 0.86 to 0.91).113 The AUROC ranged from 0.54 to 0.57. Results were similar when cases were based on presence of aberrant behaviors not necessarily resulting in opioid discontinuation. The other poor-quality study reported a higher sensitivity with the SOAPP Version 1 (0.73 at cutoff >6) compared with the ORT (0.45 at cutoff ≥4) or DIRE (0.17 at cutoff <14).114 Because patients who were not discontinued from opioids were not included in this study, specificity and other diagnostic accuracy indicators could not be determined. Both studies also included a semi-structured clinician interview that addressed many of the components included in the risk prediction instruments (e.g., pain source and duration, history of drug or alcohol abuse, psychiatric symptoms or comorbidities). In both studies, the predictive accuracy of the clinician interview was at least as good as that of formal risk instruments.

The only instruments evaluated in more than one study were the ORT (3 studies110, 113, 114) and the SOAPP version 1 (two studies).109, 114 Across the studies, estimates for diagnostic accuracy were extremely inconsistent. Using a cutoff score of >4, the sensitivity of the ORT ranged from 0.20 to 0.99 in three studies110, 113, 114 and specificity was 0.88 and 0.16 in two studies and could not be calculated in the third study (SOE: Insufficient).110, 113 The inconsistency could be due in part to differences in study methods and definitions of opioid abuse or misuse. For the SOAPP, cutoff scores of ≥6 and ≥8 had similar sensitivities (0.73 and 0.68, respectively) (SOE: Low), but other measures of diagnostic accuracy could not be compared because one of the studies only included cases.114

## Key Question 4b In patients with chronic pain, what is the effectiveness of use of risk prediction instruments on outcomes related to overdose, addiction, abuse, or misuse?

### Key Points

- No study evaluated the effectiveness of risk prediction instruments for reducing outcomes related to overdose, addiction, abuse, or misuse (SOE: Insufficient).

### Detailed Synthesis

The APS review identified no studies on the effectiveness of risk prediction instruments in reducing outcomes related to overdose, addiction abuse or misuse. We also did not identify any studies published since the APS review addressing this question.

## Key Question 4c In patients with chronic pain prescribed long-term opioid therapy, what is the effectiveness of risk mitigation strategies, including (1) opioid management plans, (2) patient education, (3) urine drug screening, (4) use of prescription drug monitoring program data, (5) use of monitoring instruments, (6) more frequent monitoring intervals, (pill counts, and (8) use of abuse-deterrent formulations on outcomes related to overdose, addiction, abuse, or misuse?

### Key Points

- No study evaluated the effectiveness of risk mitigation strategies for improving outcomes related to overdose, addiction, abuse, or misuse (SOE: Insufficient).

### Detailed Synthesis

Like the APS review, we identified no study on the effectiveness of various risk mitigation strategies for improving outcomes related to overdose, addiction, abuse, or misuse.

## Key Question 4d What is the comparative effectiveness of treatment strategies for managing patients with addiction to prescription opioids on outcomes related to overdose, abuse, misuse, pain, function, and quality of life?

### Key Points

- No study evaluated the comparative effectiveness of treatment strategies for managing patients with addiction to prescription opioids (SOE: Insufficient).

### Detailed Synthesis

Like the APS review, we identified no study on the comparative effectiveness of treatment strategies for managing patients with addiction to prescription opioids. Short-term randomized trials generally excluded patients with a past or current history of addiction.