# References

1 International Association for the Study of Pain. (1986). Classification of chronic pain: Descriptions of chronic pain syndromes and definitions of pain terms. Pain.
2 Institute of Medicine (U.S.) Committee on Advancing Pain Research Care and Education. (2011). Relieving Pain in America: A Blueprint for Transforming Prevention, Care, Education, and Research.
3 Ballantyne JC, Shin NS. (2008). Efficacy of opioids for chronic pain: A review of the evidence. Clinical J Pain.
4 Eriksen J, Sjogren P, Bruera E, et al. (2006). Critical issues on opioids in chronic non-cancer pain: an epidemiological study. Pain.
5 Sullivan MD, Edlund MJ, Fan M-Y, et al. (2008). Trends in use of opioids for non-cancer pain conditions 2000–2005 in Commercial and Medicaid insurance plans: The TROUP study. Pain.
6 Boudreau D, Von Korff M, Rutter CM, et al. (2009). Trends in long-term opioid therapy for chronic non-cancer pain. Pharmacoepidemiol Drug Saf.
7 Olsen Y, Daumit GL, Ford DE. (2006). Opioid prescriptions by U.S. primary care physicians from 1992 to 2001. J Pain.
8 Noble M, Treadwell JR, Tregear SJ, et al. Long-term opioid management for chronic noncancer pain. Cochrane Database Syst Rev.
9 Chou R, Fanciullo GJ, Fine PG, et al. (2009). Clinical guidelines for the use of chronic opioid therapy in chronic noncancer pain. J Pain.
10 Starrels JL, Becker WC, Weiner MG, et al. (2011). Low use of opioid risk reduction strategies in primary care even for high-risk patients with chronic pain. J Gen Intern Med.
11 Deyo RA, Smith DH, Johnson ES, et al. (2013). Prescription opioids for back pain and use of medications for erectile dysfunction. Spine.
12 Substance Abuse and Mental Health Services Administration. (2011). Treatment Episode Data Set (TEDS). 1999 - 2009. National Admissions to Substance Abuse Treatment Services.
13 Substance Abuse and Mental Health Services Administration. (2012). The DAWN Report: Highlights of the 2010 Drug Abuse Warning Network (DAWN) Findings on Drug-Related Emergency Department Visits.
14 Starrels JL, Becker WC, Alford DP, et al. (2010). Systematic review: treatment agreements and urine drug testing to reduce opioid misuse in patients with chronic pain. Ann Intern Med.
15 Warner M, Chen LH, Makuc DM, et al. (2011). Drug poisoning deaths in the United States, 1980–2008. NCHS Data Brief.
16 Bohnert ASB VM, Bair MJ, et al. (2011). Association between opioid prescribing patterns and opioid overdose-related deaths. JAMA.
17 Volkow ND, McLellan TA. (2011). Curtailing diversion and abuse of opioid analgesics without jeopardizing pain treatment. JAMA.
18 Saunders KW, Dunn KM, Merrill JO, et al. (2010). Relationship of opioid use and dosage levels to fractures in older chronic pain patients. J Gen Intern Med.
19 Rolita L, Spegman A, Tang X, et al. (2013). Greater number of narcotic analgesic prescriptions for osteoarthritis is associated with falls and fractures in elderly adults. J Am Geriatr Soc.
20 Gomes T, Redelmeier DA, Juurlink DN, et al. (2013). Opioid dose and risk of road trauma in Canada: a population-based study. JAMA Intern Med.
21 Centers for Disease Control and Prevention. (2014). Prescription Drug Overdose in the United States: Fact Sheet.
22 Furlan AD, Sandoval JA, Mailis-Gagnon A, et al. (2006). Opioids for chronic noncancer pain: a meta-analysis of effectiveness and side effects. CMAJ.
23 Daniell HW. (2002). Hypogonadism in men consuming sustained-action oral opioids. J Pain.
24 Daniell HW. (2008). Opioid endocrinopathy in women consuming prescribed sustained-action opioids for control of nonmalignant pain. J Pain.
25 Angst MS, Clark JD. (2006). Opioid-induced hyperalgesia: a qualitative systematic review. Anesthesiology.
26 Chou R, Ballantyne JC, Fanciullo GJ, et al. (2009). Research gaps on use of opioids for chronic noncancer pain: findings from a review of the evidence for an American Pain Society and American Academy of Pain Medicine clinical practice guideline. J Pain.
27 Furlan AD, Reardon R, Weppler C, et al. (2011). Opioids for chronic noncancer pain: a new Canadian practice guideline. CMAJ.
28 United States Department of Veterans Affairs, The Management of Opioid Therapy for Chronic Pain Working Group. (2010). VA/DoD Clinical Practice Guideline for Management of Opioid Therapy for Chronic Pain.
29 American Pain Society-American Academy of Pain Medicine Opioids Guidelines Panel. (2009). Guideline for the Use of Chronic Opioid Therapy in Chronic Noncancer Pain: Evidence Review.
30 Owens D, Lohr KN, Atkins D, et al. (2011). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
31 Chou R. The effectiveness and risks of long-term opioid treatment of chronic pain. PROSPERO 2014:CRD42014007016.
32 U.S. Food and Drug Administration. (2014). Extended-Release and Long-Acting (ER/LA) Opioid Analgesics Risk Evaluation and Mitigation Strategy (REMS) a single shared system - Current Application Holders.
33 Hall AJ, Logan JE, Toblin RL, et al. (2008). Patterns of abuse among unintentional pharmaceutical overdose fatalities. JAMA.
34 Altman DG, Bland JM. (1994). Diagnostic tests 3: receiver operating characteristic plots. BMJ.
35 Zweig MH, Campbell G. (1993). Receiver-operating characteristic (ROC) plots: a fundamental evaluation tool in clinical medicine. Clin Chem.
36 Furlan AD, Pennick V, Bombardier C, et al. (2009). 2009 updated methods guidelines for systematic reviews in the Cochrane Back Review Group. Spine.
37 U.S. Preventive Services Task Force. (2008). U.S. Preventive Services Task Force Procedure Manual.
38 Quality AfHRa. (2010). Methods Guide for Medical Test Reviews.
39 Whiting PF, Rutjes AWS, Westwood ME, et al. (2011). QUADAS-2: A revised tool for the Quality Assessment of Diagnostic Accuracy Studies. Ann Intern Med.
40 McGinn TG, Guyatt GH, Wyer PC, et al. (2000). Users' guides to the medical literature: XXII: how to use articles about clinical decision rules. JAMA.
41 Agency for Healthcare Research and Quality. (2013). Methods guide for Effectiveness and Comparative Effectiveness Reviews.
42 Atkins D, Chang SM, Gartlehner G, et al. (2011). Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
43 Allan L, Richarz U, Simpson K, et al. (2005). Transdermal fentanyl versus sustained release oral morphine in strong-opioid naive patients with chronic low back pain. Spine.
44 Furlan A, Chaparro LE, Irvin E, et al. (2011). A comparison between enriched and nonenriched enrollment randomized withdrawal trials of opioids for chronic noncancer pain. Pain Res Manag.
45 Noble M, Tregear SJ, Treadwell JR, et al. (2008). Long-term opioid therapy for chronic noncancer pain: a systematic review and meta-analysis of efficacy and safety. J Pain Symptom Manag.
46 Martell BA, O'Connor PG, Kerns RD, et al. (2007). Systematic review: opioid treatment for chronic back pain: prevalence, efficacy, and association with addiction. Ann Intern Med.
47 Carrington Reid M, Engles-Horton LL, Weber MB, et al. (2002). Use of opioid medications for chronic noncancer pain syndromes in primary care. J Gen Intern Med.
48 Edlund MJ, Martin BC, Russo JE, et al. (2014). The role of opioid prescription in incident opioid abuse and dependence among individuals with chronic noncancer pain. Clin J Pain.
49 Banta-Green CJ, Merrill JO, Doyle SR, et al. (2009). Opioid use behaviors, mental health and pain--development of a typology of chronic pain patients. Drug Alcohol Depend.
50 Boscarino JA, Rukstalis M, Hoffman SN, et al. (2010). Risk factors for drug dependence among out-patients on opioid therapy in a large U.S. health-care system. Addiction.
51 Compton PA, Wu SM, Schieffer B, et al. (2008). Introduction of a self-report version of the Prescription Drug Use Questionnaire and relationship to medication agreement noncompliance. J Pain Symptom Manage.
52 Cowan DT, Wilson-Barnett J, Griffiths P, et al. (2003). A survey of chronic noncancer pain patients prescribed opioid analgesics. Pain Med.
53 Fleming MF, Balousek SL, Klessig CL, et al. (2007). Substance use disorders in a primary care sample receiving daily opioid therapy. J Pain.
54 Hojsted J, Nielsen PR, Guldstrand SK, et al. (2010). Classification and identification of opioid addiction in chronic pain patients. Eur J Pain.
55 Portenoy RK, Farrar JT, Backonja MM, et al. (2007). Long-term use of controlled-release oxycodone for noncancer pain: results of a 3-year registry study. Clin J Pain.
56 Saffier K, Colombo C, Brown D, et al. (2007). Addiction Severity Index in a chronic pain sample receiving opioid therapy. J Subst Abuse Treat.
57 Schneider JP, Kirsh KL. (2010). Defining clinical issues around tolerance, hyperalgesia, and addiction: a quantitative and qualitative outcome study of long-term opioid dosing in a chronic pain practice. J Opioid Manag.
58 Wasan AD, Butler SF, Budman SH, et al. (2009). Does report of craving opioid medication predict aberrant drug behavior among chronic pain patients?. Clin J Pain.
59 American Psychiatric Association. (2013). Diagnostic and statistical manual of mental disorders.
60 Chou R. (2009). 2009 Clinical Guidelines from the American Pain Society and the American Academy of Pain Medicine on the use of chronic opioid therapy in chronic noncancer pain: what are the key messages for clinical practice?. Pol Arch Med Wewn.
61 Dunn KM, Saunders KW, Rutter CM, et al. (2010). Opioid prescriptions for chronic pain and overdose: a cohort study. Ann Intern Med.
62 Kalso E, Edwards JE, Moore RA, et al. (2004). Opioids in chronic non-cancer pain: systematic review of efficacy and safety. Pain.
63 Moore RA, McQuay HJ. (2005). Prevalence of opioid adverse events in chronic non-malignant pain: systematic review of randomised trials of oral opioids. Arthritis Res Ther.
64 Takkouche B, Montes-Martinez A, Gill SS, et al. (2007). Psychotropic medications and the risk of fracture: a meta-analysis. Drug Saf.
65 Vestergaard P, Rejnmark L, Mosekilde L. (2006). Fracture risk associated with the use of morphine and opiates. J Intern Med.
66 Miller M, Sturmer T, Azrael D, et al. (2011). Opioid analgesics and the risk of fractures in older adults with arthritis. J Am Ger Soc.
67 Solomon DH, Rassen JA, Glynn RJ, et al. (2010). The comparative safety of opioids for nonmalignant pain in older adults. Arch Intern Med.
68 Solomon DH, Rassen JA, Glynn RJ, et al. (2010). The comparative safety of analgesics in older adults with arthritis. Arch Intern Med.
69 Spector W, Shaffer T, Potter DE, et al. (2007). Risk factors associated with the occurrence of fractures in U.S. nursing homes: resident and facility characteristics and prescription medications. J Am Geriatr Soc.
70 Abrahamsen B, Brixen K. (2009). Mapping the prescriptiome to fractures in men--a national analysis of prescription history and fracture risk. Osteoporos Int.
71 Li L, Setoguchi S, Cabral H, et al. (2013). Opioid use for noncancer pain and risk of fracture in adults: a nested case-control study using the general practice research database. Am J Epidemiol.
72 Fishbain DA, Cutler RB, Rosomoff HL, et al. (2002). Can patients taking opioids drive safely? A structured evidence-based review. J Pain Palliat Care Pharmacother.
73 Fishbain DA, Cutler RB, Rosomoff HL, et al. (2003). Are opioid-dependent/tolerant patients impaired in driving-related skills? A structured evidence-based review. J Pain Symptom Manag.
74 Byas-Smith MG, Chapman SL, Reed B, et al. (2005). The effect of opioids on driving and psychomotor performance in patients with chronic pain. Clin J Pain.
75 Gaertner J, Frank M, Bosse B, et al. (2006). [Oral controlled-release oxycodone for the treatment of chronic pain. Data from 4196 patients]. Schmerz.
76 Galski T, Williams JB, Ehle HT. (2000). Effects of opioids on driving ability. J Pain Symptom Manag.
77 Sabatowski R, Schwalen S, Rettig K, et al. (2003). Driving ability under long-term treatment with transdermal fentanyl. J Pain Symptom Manag.
78 Menefee LA, Frank ED, Crerand C, et al. (2004). The effects of transdermal fentanyl on driving, cognitive performance, and balance in patients with chronic nonmalignant pain conditions. Pain Med.
79 Carman WJ, Su S, Cook SF, et al. (2011). Coronary heart disease outcomes among chronic opioid and cyclooxygenase-2 users compared with a general population cohort. Pharmacoepidemiol Drug Saf.
80 Li L, Setoguchi S, Cabral H, et al. (2013). Opioid use for noncancer pain and risk of myocardial infarction amongst adults. J Intern Med.
81 Merza Z, Edwards N, Walters S, et al. (2003). Patients with chronic pain and abnormal pituitary function require investigation. The Lancet.
82 Daniell HW. (2006). DHEAS deficiency during consumption of sustained-action prescribed opioids: evidence for opioid-induced inhibition of adrenal androgen production. J Pain.
83 Rhodin A, Stridsberg M, Gordh T. (2010). Opioid endocrinopathy: a clinical problem in patients with chronic pain and long-term oral opioid treatment. Clin J Pain.
84 Gomes T, Mamdani MM, Dhalla IA, et al. (2011). Opioid dose and drug-related mortality in patients with nonmalignant pain. Arch Intern Med.
85 Paulozzi LJ, Kilbourne EM, Shah NG, et al. (2012). A history of being prescribed controlled substances and risk of drug overdose death. Pain Med.
86 Braden JB, Russo J, Fan MY, et al. (2010). Emergency department visits among recipients of chronic opioid therapy. Arch Intern Med.
87 Salzman RT, Roberts MS, Wild J, et al. (1999). Can a controlled-release oral dose form of oxycodone be used as readily as an immediate-release form for the purpose of titrating to stable pain control?. J Pain Symptom Manag.
88 Jamison RN, Raymond SA, Slawsby EA, et al. (1998). Opioid therapy for chronic noncancer back pain. A randomized prospective study. Spine.
89 Chou R, Clark E, Helfand M. (2003). Comparative efficacy and safety of long-acting oral opioids for chronic non-cancer pain: a systematic review. J Pain Symptom Manag.
90 Caldwell JR, Hale ME, Boyd RE, et al. (1999). Treatment of osteoarthritis pain with controlled release oxycodone or fixed combination oxycodone plus acetaminophen added to nonsteroidal anti-inflammatory drugs: a double blind, randomized, multicenter, placebo controlled trial. J Rheumatol.
91 Gostick N, Allen J, Cranfield R, et al. (1989). A comparison of the efficacy and adverse effects of controlled-release dihydrocodeine and immediate-release dihydrocodeine in the treatment of pain in osteoarthritis and chronic back pain. Proceedings of The Edinburgh Symposium on Pain Control and Medical Education.
92 Hale M, Speight K, Harsanyi Z, et al. (1997). Efficacy of 12 hourly controlled-release codeine compared with as required dosing of acetaminophen plus codeine in patients with chronic low back pain. Pain Res Manag.
93 Hale ME, Fleischmann R, Salzman R, et al. (1999). Efficacy and safety of controlled-release versus immediate-release oxycodone: randomized, double-blind evaluation in patients with chronic back pain. Clin J Pain.
94 Lloyd R, Costello F, Eves M, et al. (1992). The efficacy and tolerability of controlled-release dihydrocodeine tablets and combination dextro-propoxyphene/paracetamol tablets in patients with severe osteoarthritis of the hips. Curr Med Res Op.
95 Hartung DM, Middleton L, Haxby DG, et al. (2007). Rates of Adverse Events of Long-Acting Opioids in a State Medicaid Program. Ann Pharmacother.
96 Mitra F, Chowdhury S, Shelley M, et al. (2013). A feasibility study of transdermal buprenorphine versus transdermal fentanyl in the long-term management of persistent non-cancer pain. Pain Med.
97 Wild JE, Grond S, Kuperwasser B, et al. (2010). Long-term safety and tolerability of tapentadol extended release for the management of chronic low back pain or osteoarthritis pain. Pain Pract.
98 Krebs EE, Becker WC, Zerzan J, et al. (2011). Comparative mortality among Department of Veterans Affairs patients prescribed methadone or long-acting morphine for chronic pain. Pain.
99 Naliboff BD, Wu SM, Schieffer B, et al. (2011). A randomized trial of 2 prescription strategies for opioid treatment of chronic nonmalignant pain. J Pain.
100 Portenoy RK, Messina J, Xie F, et al. (2007). Fentanyl buccal tablet (FBT) for relief of breakthrough pain in opioid-treated patients with chronic low back pain: a randomized, placebo-controlled study. Curr Med Res Opin.
101 Simpson DM, Messina J, Xie F, et al. (2007). Fentanyl buccal tablet for the relief of breakthrough pain in opioid-tolerant adult patients with chronic neuropathic pain: a multicenter, randomized, double-blind, placebo-controlled study. Clin Ther.
102 Ashburn MA, Slevin KA, Messina J, et al. (2011). The efficacy and safety of fentanyl buccal tablet compared with immediate-release oxycodone for the management of breakthrough pain in opioid-tolerant patients with chronic pain. Anesth Analg.
103 Davies A, Sitte T, Elsner F, et al. (2011). Consistency of efficacy, patient acceptability, and nasal tolerability of fentanyl pectin nasal spray compared with immediate-release morphine sulfate in breakthrough cancer pain. J Pain Symptom Manag.
104 Webster LR, Slevin KA, Narayana A, et al. (2013). Fentanyl buccal tablet compared with immediate-release oxycodone for the management of breakthrough pain in opioid-tolerant patients with chronic cancer and noncancer pain: a randomized, double-blind, crossover study followed by a 12-week open-label phase to evaluate patient outcomes. Pain Med.
105 Cowan DT, Wilson-Barnett J, Griffiths P, et al. (2005). A randomized, double-blind, placebo-controlled, cross-over pilot study to assess the effects of long-term opioid drug consumption and subsequent abstinence in chronic noncancer pain patients receiving controlled-release morphine. Pain Med.
106 Ralphs JA, Williams AC, Richardson PH, et al. (1994). Opiate reduction in chronic pain patients: a comparison of patient-controlled reduction and staff controlled cocktail methods. Pain.
107 Tennant FS, Rawson RA. (1982). Outpatient treatment of prescription opioid dependence: comparison of two methods. Arch Intern Med.
108 Chou R, Fanciullo GJ, Fine PG, et al. (2009). Opioids for chronic noncancer pain: prediction and identification of aberrant drug-related behaviors: a review of the evidence for an American Pain Society and American Academy of Pain Medicine clinical practice guideline. J Pain.
109 Akbik H, Butler SF, Budman SH, et al. (2006). Validation and clinical application of the Screener and Opioid Assessment for Patients with Pain (SOAPP). J Pain Symptom Manag.
110 Webster LR, Webster RM. (2005). Predicting aberrant behaviors in opioid-treated patients: preliminary validation of the Opioid Risk Tool. Pain Med.
111 Butler SF, Budman SH, Fernandez K, et al. (2004). Validation of a screener and opioid assessment measure for patients with chronic pain. Pain.
112 Butler SF, Fernandez K, Benoit C, et al. (2008). Validation of the revised Screener and Opioid Assessment for Patients with Pain (SOAPP-R). J Pain.
113 Jones T, Moore T, Levy JL, et al. (2012). A comparison of various risk screening methods in predicting discharge from opioid treatment. Clin J Pain.
114 Moore TM, Jones T, Browder JH, et al. (2009). A comparison of common screening methods for predicting aberrant drug-related behavior among patients receiving opioids for chronic pain management. Pain Med.
115 Franklin GM, Mai J, Turner J, et al. (2012). Bending the prescription opioid dosing and mortality curves: impact of the Washington State opioid dosing guideline. Am J Ind Med.
116 Chou R, Cruciani RA, Fiellin DA, et al. (2014). Methadone safety: a clinical practice guideline from the American Pain Society and College on Problems of Drug Dependence, in collaboration with the Heart Rhythm Society. J Pain.
117 Chou R, Weimer MB, Dana T. (2014). Methadone overdose and cardiac arrhythmia potential: findings from a review of the evidence for an American Pain Society and College on Problems of Drug Dependence clinical practice guideline. J Pain.
118 U.S. Food and Drug Administration. (2013). Public Health Advisory: Important Information for the Safe Use of Fentora (fentanyl buccal tablets).
119 Jones T, Moore T. (2013). Preliminary data on a new opioid risk assessment measure: the Brief Risk Interview. J Opioid Manag.
120 Butler SF, Budman SH, Fanciullo GJ, et al. (2010). Cross validation of the current opioid misuse measure to monitor chronic pain patients on opioid therapy. Clin J Pain.
121 Butler SF, Budman SH, Fernandez KC, et al. (2009). Cross-validation of a screener to predict opioid misuse in chronic pain patients (SOAPP-R). J Addict Med.
122 Fleming MF, Davis J, Passik SD. (2008). Reported lifetime aberrant drug-taking behaviors are predictive of current substance use and mental health problems in primary care patients. Pain Med.
123 Meltzer EC, Rybin D, Saitz R, et al. (2011). Identifying prescription opioid use disorder in primary care: diagnostic characteristics of the Current Opioid Misuse Measure (COMM). Pain.
124 Butler SF, Budman SH, Fernandez KC, et al. (2007). Development and validation of the Current Opioid Misuse Measure. Pain.
125 Holmes CP, Gatchel RJ, Adams LL, et al. (2006). An Opioid Screening Instrument: Long-Term Evaluation of the Utility of the Pain Medication Questionnaire. Pain Pract.
126 Reifler LM, Droz D, Bailey JE, et al. (2012). Do Prescription Monitoring Programs Impact State Trends in Opioid Abuse/Misuse?. Pain Med.
127 Deyo RA, Smith DH, Johnson ES, et al. (2011). Opioids for back pain patients: primary care prescribing patterns and use of services. J Am Board Fam Med.
128 Seal KH, Shi Y, Cohen G, et al. (2012). Association of mental health disorders with prescription opioids and high-risk opioid use in us veterans of Iraq and Afghanistan. JAMA.
129 Sullivan MD, Edlund MJ, Zhang L, et al. (2006). Association between mental health disorders, problem drug use, and regular prescription opioid use. Arch Intern Med.
130 Morasco BJ, Duckart JP, Carr TP, et al. (2010). Clinical characteristics of veterans prescribed high doses of opioid medications for chronic non-cancer pain. Pain.
131 Carson S, Thakurta S, Low A, et al. (2011). Drug Class Review: Long-Acting Opioid Analgesics: Final Update 6 Report Oregon Health & Science University.
132 Fishbain DA, Cole B, Lewis J, et al. (2008). What percentage of chronic nonmalignant pain patients exposed to chronic opioid analgesic therapy develop abuse/addiction and/or aberrant drug-related behaviors? A structured evidence-based review. Pain Med.
133 Turk DC, Swanson KS, Gatchel RJ. (2008). Predicting opioid misuse by chronic pain patients: a systematic review and literature synthesis. Clin J Pain.
134 Wiedemer NL, Harden PS, Arndt IO, et al. (2007). The opioid renewal clinic: a primary care, managed approach to opioid therapy in chronic pain patients at risk for substance abuse. Pain Med.
135 Goldberg KC, Simel DL, Oddone EZ. (2005). Effect of an opioid management system on opioid prescribing and unscheduled visits in a large primary care clinic. J Clin Outcome Manag.
136 Manchikanti L, Manchukonda R, Damron KS, et al. (2006). Does adherence monitoring reduce controlled substance abuse in chronic pain patients?. Pain Physician.
137 Manchikanti L, Manchukonda R, Pampati V, et al. (2006). Does random urine drug testing reduce illicit drug use in chronic pain patients receiving opioids?. Pain Physician.
138 Pablos-Mendez A, Barr RG, Shea S. (1998). Run-in periods in randomized trials: implications for hte application of results in clinical practice. JAMA.
139 Furlan AD, Reardon R, Weppler C. (2010). Opioids for chronic noncancer pain: a new Canadian practice guideline. CMAJ.
140 Nuckols TK, Anderson L, Popescu I, et al. (2014). Opioid prescribing: a systematic review and critical appraisal of guidelines for chronic pain. Ann Intern Med.
141 O'Connor AB, Turk DC, Dworkin RH, et al. (2013). Abuse liability measures for use in analgesic clinical trials in patients with pain: IMMPACT recommendations. Pain.
142 Cicero TJ, Ellis MS, Surratt HL. (2012). Effect of abuse-deterrent formulation of OxyContin. N Engl J Med.
143 Roland M, Torgerson DJ. (1998). Understanding controlled trials: What are pragmatic trials?. BMJ.