# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Matthew Bair, M.D., M.S.
  Associate Professor of Medicine,
  Indiana University School of Medicine
  Research Scientist,
  Indiana University Center for Health Services and Outcomes Research
  Research Scientist, Center for Health Services Research,
  Regenstrief Institute, Inc.
  Core Investigator,
  VA HSR&D Center for Health Information and Communication
  Indianapolis, IN
- Daniel Carr, M.D., M.A.
  Professor of Public Health and Community Medicine
  Program Director, Pain, Research Education & Policy
  Tufts University School of Medicine
  Boston, MA
- Gary Franklin, M.D., M.P.H.
  Research Professor, Environmental and Occupational Health Sciences
  Adjunct Research Professor, Health Services
  University of Washington
  Seattle, WA
- Aaron M. Gilson, M.S., M.S.S.W., Ph.D.
  Research Program Manager/Senior Scientist
  Pain & Policy Studies Group
  Carbone Cancer Center
  University of Wisconsin-Madison
  Madison, WI
- Douglas Gourlay M.D., M.Sc., FRCP(c), FASAM
  Former Director, Pain and Chemical Dependency Division
  Wasser Pain Center
  Toronto, Ontario, Canada
- Charles Inturrisi, Ph.D.
  Professor of Pharmacology
  Weill Cornell Medical College
  New York, NY
- Robert Jamison, Ph.D.
  Professor of Anaesthesia, Harvard Medical School
  Psychologist, Brigham and Women’s Hospital
  Boston, MA
- Erin E. Krebs, M.D., M.P.H.
  Core Investigator, Center for Chronic Disease Outcomes Research
  Minneapolis VA Health Care System
  Associate Professor of Medicine, University of Minnesota
  Minneapolis, MN
- Leonard Paulozzi, M.D., M.P.H.
  Medical Epidemiologist
  Division of Unintentional Injury Prevention
  National Center for Injury Prevention and Control
  Centers for Disease Control and Prevention
  Atlanta, GA
- Dennis Turk, Ph.D.
  Professor, Department of Anesthesiology & Pain Medicine
  University of Washington
  Seattle, WA
- Mark Wallace, M.D.
  Chair, Division of Pain Management
  University of California, San Diego
  San Diego, CA
- Lonnie Zeltzer, M.D.
  Director, Children’s Pain and Comfort Care Program
  Mattel Children’s Hospital UCLA
  Distinguished Professor of Pediatrics, Anesthesiology,
  Psychiatry and Biobehavioral Sciences
  David Geffen School of Medicine
  University of California, Los Angeles
  Los Angeles, CA