# Technical Expert Panel

In designing the review questions and methodology at the outset of this report, the EPC consulted several technical and content experts, reflecting a variety of viewpoints relevant to this topic. Technical experts consulted are expected to have divergent and possibly conflicting opinions. This diversity is helpful in achieving a well-rounded report. The study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Matthew Bair, M.D., M.S.
  Associate Professor of Medicine,
  Indiana University School of Medicine
  Research Scientist,
  Indiana University Center for Health Services and Outcomes Research
  Research Scientist,
  Center for Health Services Research
  Regenstrief Institute, Inc.
  Core Investigator,
  VA HSR&D Center for Health Information and Communication
  Indianapolis, IN
- Gilbert Fanciullo, M.D., M.S.
  Director, Pain Management Center
  Dartmouth-Hitchcock Medical Center
  Lebanon, NH
- Gary Franklin, M.D., M.P.H.
  Research Professor
  Environmental and Occupational Health Sciences
  Adjunct Research Professor, Health Services
  University of Washington
  Seattle, WA
- Charles Inturrisi, Ph.D.
  Professor of Pharmacology
  Weill Cornell Medical College
  New York, NY
- Robert Jamison, Ph.D.
  Professor of Anaesthesia
  Harvard Medical School
  Psychologist
  Brigham and Women’s Hospital
  Boston, MA
- Erin E. Krebs, M.D., M.P.H.
  Core Investigator, Center for Chronic Disease Outcomes Research
  Minneapolis VA Health Care System
  Associate Professor of Medicine,
  University of Minnesota
  Minneapolis, MN
- Leonard Paulozzi, M.D., M.P.H.
  Medical Epidemiologist
  Division of Unintentional Injury Prevention
  National Center for Injury Prevention and Control
  Centers for Disease Control and Prevention
  Atlanta, GA
- Mark Wallace, M.D.
  Chair, Division of Pain Management
  University of California, San Diego
  San Diego, CA
- Lonnie Zeltzer, M.D.
  Director, Children's Pain and Comfort Care Program
  Mattel Children's Hospital UCLA
  Distinguished Professor of Pediatrics,
  Anesthesiology, Psychiatry and Biobehavioral Sciences
  David Geffen School of Medicine
  University of California, Los Angeles
  Los Angeles, CA