# Key Informants

This topic was nominated to AHRQ from the National Institutes of Health. Therefore, in place of Key Informants, a National Institutes of Health Working Group Planning Meeting was conducted to provide input into the key questions and the scope of the report.