# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Suchitra Iyer, Ph.D., Task Order Officer; David Reuben, M.D., National Institutes of Health Working Group Chair; and the National Institutes of Health Working Group.