# Appendix G Strength of Evidence Table

Key Question Outcome | Study Design Number of Studies (N) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade
1. Effectiveness and comparative effectiveness
a. In patients with chronic pain, what is the effectiveness of long-term opioid therapy versus placebo or no opioid therapy for long-term (>1 year) outcomes related to pain, function, and quality of life?
Pain, function, quality of life | No studies | - | - | - | - | - | Insufficient
b. How does effectiveness vary depending on: 1) the specific type or cause of pain (e.g., neuropathic, musculoskeletal [including low back pain], fibromyalgia, sickle cell disease, inflammatory pain, and headache disorders); 2) patient demographics (e.g., age, race, ethnicity, gender); 3) patient comorbidities (including past or current alcohol or substance use disorders, mental health disorders, medical comorbidities and high risk for addiction)?
Pain, function, quality of life | No studies | - | - | - | - | - | Insufficient
c. In patients with chronic pain, what is the comparative effectiveness of opioids versus nonopioid therapies (pharmacological or nonpharmacological) on outcomes related to pain, function, and quality of life?
Pain, function, quality of life | No studies | - | - | - | - | - | Insufficient
d. In patients with chronic pain, what is the comparative effectiveness of opioids plus nonopioid interventions (pharmacological or nonpharmacological) versus opioids or nonopioid interventions alone on outcomes related to pain, function, quality of life, and doses of opioids used?
Pain, function, quality of life | No studies | - | - | - | - | - | Insufficient
2. Harms and adverse events
a. In patients with chronic pain, what are the risks of opioids versus placebo or no opioid on: 1) opioid abuse, addiction, and related outcomes; 2) overdose; and 3) other harms, including gastrointestinal-related harms, falls, fractures, motor vehicle accidents, endocrinological harms, infections, cardiovascular events, cognitive harms, and psychological harms (e.g., depression)?
Abuse, addiction | 1 cohort study (n=568,640) | Moderate | Unknown (1 study) | Direct | Precise | Undetected | Low
Abuse, addiction | 10 uncontrolled studies | High | Inconsistent | Direct | Precise | Undetected | Insufficient
Overdose | 1 cohort study (n=9,940) | Moderate | Unknown (1 study) | Direct | Imprecise | Undetected | Low
Fractures | 1 cohort study (n=2,341) and 1 case-control study (21,739 cases) | Moderate | Consistent | Direct | Precise | Undetected | Low
Myocardial infarction | 1 cohort study (n=426,124) and 1 case-control study (11,693 cases) | Low | Consistent | Direct | Precise | Undetected | Low
Endocrine | 1 cross-section study (n=11,327) | Moderate | Unknown (1 study) | Direct | Precise | Undetected | Low
Gastrointestinal harms, motor vehicle accients, infections, psychological harms, cognitive harms | No studies | - | - | - | - | - | Insufficient
b. How do harms vary depending on: 1) the specific type or cause of pain(e.g., neuropathic, musculoskeletal [including back pain], fibromyalgia, sickle cell disease, inflammatory pain, headache disorders); 2) patient demographics; 3) patient comorbidities (including past or current substance use disorder or at high risk for addiction)?
Various harms | No studies | - | - | - | - | - | Insufficient
b. How do harms vary depending on the dose of opioids used?
Abuse, addiction | 1 cohort study (n=568,640) | Moderate | Unknown (1 study) | Direct | Precise | Undetected | Low
Overdose | 1 cohort study (n=9,940) and 1 case-control study (593 cases in primary analysis) | Moderate | Consistent | Direct | Precise | Undetected | Low
Fracture | 1 cohort study (n=2,341) | Moderate | Unknown (1 study) | Direct | Imprecise | Undetected | Low
Myocardial infarction | 1 cohort study (n=426,124) | Moderate | Unknown (1 study) | Direct | Precise | Undetected | Low
Motor vehicle accidents | 1 case-control study (5,300 cases) | Low | Unknown (1 study) | Direct | Precise | Undetected | Low
Endocrine | 1 cross-sectional study (n=11,327) | Moderate | Unknown (1 study) | Direct | Precise | Undetected | Low
3. Dosing strategies
a. In patients with chronic pain, what is the comparative effectiveness of different methods for initiating and titrating opioids for outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?
Pain | 2 randomized trials (n=93) | Moderate | Inconsisten | Direct | Imprecise | Undetected | Insufficient
Function, quality of life, outcomes related to abuse | No studies | - | - | - | - | - | Insufficient
b. In patients with chronic pain, what is the comparative effectiveness of short- versus long-acting opioids on outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?
Pain, function, quality of life, outcomes related to abuse | No studies | - | - | - | - | - | Insufficient
c. In patients with chronic pain, what is the comparative effectiveness of different long-acting opioids on outcomes related to pain, function, and quality of life; and risk of overdose, addiction, abuse, or misuse?
Pain and function | 3 randomized trials | Moderate | Consistent | Direct | Precise | Undetected | Low
Assessment of risk of overdose, addiction, abuse, or misuse | No studies | - | - | - | - | - | Insufficient
Overdose (as indicated by all-cause mortality) | 1 cohort study (n=108,492) | Moderate | Unknown (1 study) | Direct | Precise | Undetected | Low
Abuse and related outcomes | 1 cohort study (n=5,684) | Moderate | Unknown (1 study) | Direct | Imprecise | Undetected | Insufficient
d. In patients with chronic pain, what is the comparative effectiveness of short- plus long-acting opioids vs. long-acting opioids alone on outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?
Pain, function, quality of life, outcomes related to abuse | No studies | - | - | - | - | - | Insufficient
e. In patients with chronic pain, what is the comparative effectiveness of scheduled, continuous versus as- needed dosing of opioids on outcomes related to pain, function, and quality of life; risk of overdose, addiction, abuse, or misuse; and doses of opioids used?
Pain, function, quality of life, outcomes related to abuse | No studies | - | - | - | - | - | Insufficient
f. In patients with chronic pain on long-term opioid therapy, what is the comparative effectiveness of dose escalation versus dose maintenance or use of maximum dose ceilings on outcomes related to pain, function, and quality of life?
Pain, function, withdrawal due to opioid misuse | 1 randomized trial (n=140) | Moderate | Unknown (1 study) | Direct | Imprecise | Undetected | Low
g. In patients on long-term opioid therapy, what is the comparative effectiveness of opioid rotation versus maintenance of current opioid therapy on outcomes related to pain, function, and quality of life; and doses of opioids used?
Pain, function, quality of life, outcomes related to abuse | No studies | - | - | - | - | - | Insufficient
h. In patients on long-term opioid therapy, what is the comparative effectiveness of different strategies for treating acute exacerbations of chronic pain on outcomes related to pain, function, and quality of life?
Pain | 5 randomized trials (n=802) | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Function, quality of life, abuse and related outcomes | No studies | - | - | - | - | - | Insufficient
i. In patients on long-term opioid therapy, what are the effects of decreasing opioid doses or of tapering off opioids versus continuation of opioids on outcomes related to pain, function, quality of life, and withdrawal symptoms?
Pain, function | 1 randomized trial (n=10) | High | Unknown (1 study) | Direct | Imprecise | Undetected | Insufficient
j. In patients on long-term opioid therapy, what is the comparative effectiveness of different tapering protocols and strategies on measures related to pain, function, quality of life, withdrawal symptoms, and likelihood of opioid cessation?
Opioid abstinence | 2 nonrandomized trials (n=150) | High | Consistent | Direct | Imprecise | Undetected | Insufficient
4. Risk assessment and risk mitigation strategies
a. In patients with chronic pain being considered for long-term opioid therapy, what is the accuracy of instruments for predicting risk of opioid overdose, addiction, abuse, or misuse?
Diagnostic accuracy: Opioid Risk Tool | 3 studies of diagnostic accuracy (n=496) | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Diagnostic accuracy: Screening and Opioid Assesment for Patients with Pain version 1 | 2 studies of diagnostic accuracy (n=203) | High | Consistent | Direct | Imprecise | Undetected | Low
b. In patients with chronic pain, what is the effectiveness of use of risk prediction instruments on outcomes related to overdose, addiction, abuse, or misuse?
Outcomes related to abuse | No studies | - | - | - | - | - | Insufficient
c. In patients with chronic pain prescribed long-term opioid therapy, what is the effectiveness of risk mitigation strategies, including 1) opioid management plans, 2) patient education, 3) urine drug screening, 4) use of prescription drug monitoring program data, 5) use of monitoring instruments, 6) more frequent monitoring intervals, 7) pill counts, and 8) use of abuse-deterrent formulations on outcomes related to overdose, addiction, abuse, or misuse?
Outcomes related to abuse | No studies | - | - | - | - | - | Insufficient
d. What is the comparative effectiveness of treatment strategies for managing patients with addiction to prescription opioids on outcomes related to overdose, abuse, misuse, pain, function, and quality of life?
Outcomes related to abuse | No studies | - | - | - | - | - | Insufficient