# Appendix F Quality Assessment Tables

Appendix Table F1 Quality Assessment of Cohort Studies

Author, Year | KQ | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (e.g., by restriction or matching)? | Did the study maintain comparable groups through the study period? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Is there important differential loss to followup or overall high loss to followup? | Did the study perform appropriate statistical analyses on potential confounders? | Were outcomes prespecified and defined, and ascertained using accurate methods? | Quality
Carman, 2011 | KQ2a, b myocardial infarction | Yes | Yes | Yes | Yes | Unclear | No | Unclear | Yes | Yes | Fair
Dunn, 2010 | KQ2a, b overdose | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Fair
Edlund, 2014 | KQ2a, b abuse | Yes | Unclear | Yes | Yes | Unclear | No | No | Yes | Yes | Fair
Hartung, 2007 | KQ3c | Yes | No | Yes | Yes | Unclear | No | Unclear | Yes | Yes | Fair
Krebs, 2011 | KQ3c | Yes | No | Yes | Yes | No | Yes | No | Yes | Yes | Fair
Saunders, 2010 | KQ2a, b fractures | Yes | Unclear | Yes | Yes | Unclear | No | Unclear | Yes | Yes | Fair

Note: The references are available in Appendix C.

Based on United States Preventive Services Task Force Quality Assessment Criteria (see Methods section for details).

KQ=key question

Appendix Table F2 Quality Assessment of Cross-Sectional Studies

Author, Year | KQ | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were outcome assessors blinded to patient characteristics? | Did the article report attrition? | Is there overall high loss to followup? | Were prespecified outcomes assessed in all patients? | Quality
Banta-Green, 2009 | KQ2a abuse | Yes | Unclear | NA | NA | Yes | Fair
Boscarino, 2010 | KQ2a abuse | Yes; random | No | NA | NA | No (high proportion of nonrespondents) | Fair
Carrington Reid, 2002 | KQ2a abuse | Yes | No | NA | NA | Yes | Fair
Compton, 2008 | KQ2a abuse | Yes; consecutive | No | No | Unclear | Yes | Fair
Cowan, 2003 | KQ2a abuse | Yes | Unclear | NA | NA | Yes | Fair
Deyo, 2013 | KQ2a, b endocrine | Yes | Unclear | NA | NA | Yes | Fair
Fleming, 2007 See also: Saffier, 2007 | KQ2a abuse | Yes; all | No | NA | NA | Yes | Fair
Hojsted, 2010 | KQ2a abuse | Unclear | No | NA | NA | Yes | Fair
Portenoy, 2007 | KQ2a abuse | No (28% of eligible patients enrolled, not clear why most did not enroll) | No | Yes | Yes (Table 3) | Yes | Fair
Schneider, 2010 | KQ2a abuse | Yes | No | NA | NA | No; UDT only in 82% of patients | Fair
Wasan, 2009 | KQ2a abuse | Unclear | Yes | NA | NA | No | Fair

Note: The references are located in Appendix C.

Based on United States Preventive Services Task Force Quality Assessment Criteria (see Methods section for details).

KQ=key question; NA=not applicable; UDT=urine drug test

Appendix Table F3 Quality Assessment of Case Control Studies

Author, Year | KQ | Did the study attempt to enroll all or random sample of cases using predefined criteria? | Were the controls derived from the same population as the cases? | Were the groups comparable at baseline on key prognostic factors? | Were enrollment rates similar in cases and controls invited to participate? | Did the study use accurate methods for identifying outcomes? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Did the study perform appropriate statistical analyses on potential confounders? | Quality
Gomes, 2011 | KQ2b overdose | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Good
Gomes, 2013 | KQ2b, motor vehicle accident | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Good
Li, 2013a | KQ2a fractures | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Good
Li, 2013b | KQ2a myocardial infarction | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Good

Note: The references are available in Appendix C.

Based on United States Preventive Services Task Force Quality Assessment Criteria (see Methods section for details).

KQ=key question

Appendix Table F4 Quality Assessment of Trials

Author, year | KQ | Randomization | Concealed treatment allocation | Baseline group similarity | Patient blinded | Care provider blinded | Outcome assessor blinded | Cointerventions avoided or similar | Compliance acceptable in all groups | Attrition reported | Attrition acceptable | Timing of outcome assessment in all groups similliar | Intention to treat analysis | Avoidance of selective outcomes reporting | Quality
Allan, 2005 | KQ3c | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Yes | Yes | Fair
Ashburn, 2011 | KQ3h | Yes | Yes | Yes | Yes | Yes | Unclear; probably yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Cowan, 2005 | KQ3i | Yes | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | no | Unclear | Yes | Yes | Unclear | Poor
Davies, 2011 | KQ3h | Unclear | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Jamison, 1998 | KQ3a | Unclear | Unclear | Unclear | No | No | No | No | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Mitra, 2013 | KQ3c | Yes | No | Unclear | Unclear | No | Yes | Yes | No | Yes | No | Yes | No | No | Poor
Naliboff 2011 | KQ3f | Yes | Yes | Yes | Yes | No | Unclear | Yes (similar in both groups) | Unclear | Yes | No | Yes | Yes | Yes | Fair
Portenoy, 2007 | KQ3h | Yes | Yes | NA | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Good
Ralphs, 1994 | KQ3j | No | No | No | No | No | No | Yes | Unclear | No | Unclear | Yes | Yes | Unclear | Poor
Salzman, 1999 | KQ3a | Unclear | Unclear | Yes | No | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Simpson, 2007 | KQ3h | Yes | Unclear | NA | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Tennant, 1982 | KQ3j | No | No | No | No | No | No | Unclear | Unclear | No | Unclear | Yes | Yes | Unclear | Poor
Webster, 2013 | KQ3h | Yes | Yes | Yes | Yes | Yes | Unclear; probably yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Wild 2010 | KQ3c | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Yes | Yes | Fair

Note: The references are available in Appendix C.

Based on Cochrane Back Review Group Quality Assessment Methods (see Methods section for details).

KQ=key question

Appendix Table F5 Quality Assessment of Screening Instrument Studies

Author, year | Evaluates population other than the one used to derive the instrument | Avoided case-control design | Consecutive series of patients or a random subset | Describes severity of symptoms, opioid dose/duration and underlying conditions | Adequate descripton of screening instrument | Apprioriate criteria included in screening instrument | Adequate descripton of methods for identifying aberrant drug-related behaviors | Appropriate criteria used to identify aberrant drug related behaviors | Aberrant drug-related behaviors assessed in all enrollees | Blinded assessment of aberrant drug-related behaviors | Quality
Akbik, 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | No | Unclear | Fair
Jones, 2012 | Yes | No | No | Yes | Yes | Yes | Yes | No | No | Unclear | Poor
Moore, 2009 | Yes | No | No | Yes | Yes | Yes | Yes | No | No | Unclear | Poor
Webster, 2005 | Yes | Yes | Yes | Yes | Yes | Yes | No | Unclear | Unclear | Unclear | Fair

Note: The references are available in Appendix C.

Based on various methods sources (see Methods section for details).