# Appendix E Data Abstraction Tables

Appendix Table E1 Uncontrolled Studies of Long-term Opioid Use and Abuse, Misuse, and Related Outcomes

Appendix Table E2 Observational Studies of Long-Term Opioid Use and Overdose

Appendix Table E3 Observational Studies of Long-Term Opioid Use and Fractures

Appendix Table E4 Observational Studies of Long-Term Opioid Use and Cardivascular Outcomes

Appendix Table E5 Observational Studies of Long-Term Opioid Use and Endocrine Outcomes

Appendix Table E6 Observational Studies of Long-Term Opioid Use and Motor Vehicle Accidents

Appendix Table E7 Trials of Different Methods for Initiating and Titrating Opioids

Appendix Table E8a Head-to-Head Trials of Different Long-Acting Opioids

Appendix Table E8b Observational Studies of Different Long-acting Opioids

Appendix Table E9 Trials of Opioid Dose Escalation Versus Dose Maintenance or Use of Maximum Dose Ceilings

Appendix Table E10 Trials of Different Strategies for Treating Acute Exacerbations of Chronic Pain in Patients on Long-term Opioid Therapy

Appendix Table E11 Trials of Decreasing Opioid Doses or of Tapering Off Opioids Versus Continuation of Opioids

Appendix Table E12 Nonrandomized Trials of Different Opioid Tapering Protocols and Strategies

Appendix Table E13 Prospective Studies on Use of Screening Instruments To Predict the Risk of Aberrant Drug-Related Behaviors